# References

Abramsohn L, Murphy BJ, Pandeya NK, Stallings JO, Bergman RS. The tensor fascia lata myocutaneous flap: experience with its use as a rotation flap. J Am Osteopath Assoc 1981 Jul;80(11):733-5.
Acute Pain Management Guideline Panel. Acute pain management: operative or medical procedures and trauma. Clinical Practice Guideline, No. 1. Rockville (MD): Agency for Health Care Policy and Research, Public Health Service, US Department of Health and Human Services; 1992 Feb. AHCPR Publication No. 92-0032. 145 p.
Adler PF. Assessing the effects of pentoxifylline (Trental) on diabetic neurotrophic foot ulcers. J Foot Surg 1991 May-Jun;30(3):300-3.
Agren MS, Stromberg HE. Topical treatment of pressure ulcers: a randomized comparative trial of Varidase and zinc oxide. Scand J Plast Reconstr Surg 1985;19(1):97-100.
Ahmed MC. Op-Site for decubitus care. Am J Nurs 1982 Jan;82(1):61-4.
Allman RM. Epidemiology of pressure sores in different populations. Decubitus 1989 May;2(2):30-3.
Allman RM, Laprade CA, Noel LB, Walker JM, Moorer CA, Dear MR, Smith CR. Pressure sores among hospitalized patients. Ann Intern Med 1986 Sep;105(3):337-42.
Allman RM, Walker JM, Hart MK, Laprade CA, Noel LB, Smith CR. Air-fluidized beds or conventional therapy for pressures sores: a randomized trial. Ann Intern Med 1987 Nov;107(5):641-8.
Alm A, Hornmark AM, Fall PA, Linder L, Bergstrand B, Ehrnebo M, Madsen SM, Setterberg G. Care of pressure sores: a controlled study of the use of a hydrocolloid dressing compared with wet saline gauze compresses. Acta Derm Venereol (Stockh) 1989;149 Suppl:1-10.
Alvarez OM, Mertz PM, Eaglstein WH. The effect of occlusive dressings on collagen synthesis and re-epithelialization in superficial wounds. J Surg Res 1983;35(2):142-8.
Ameis A, Chiarcossi A, Jimenez J. Management of pressure sores: comparative study in medical and surgical patients. Postgrad Med 1980 Feb;67(2):177-84.
Andberg MM, Rudolph A, Anderson T. Improving skin care through patient and family training. Top Clin Nurs 1983;5(2):45-54.
Anderson TP, Andberg MM. Psychosocial factors associated with pressure sores. Arch Phys Med Rehabil 1979 Aug;60(8):341-6.
Anderson TP, Andberg MM. An investigation of decubitus ulcer as a manifestation of a psychosocial problem: final report. Minneapolis, (MN): University of Minnesota Health Sciences Center, Department of Medicine and Rehabilitation; 1980. 55 p.
Anthony JP, Huntsman WT, Mathes SJ. Changing trends in the management of pelvic pressure ulcers: a 12-year review. Decubitus 1992 May;5(3):44-7, 50-1.
Arikian VL, Kingery C, Beall K, Abbott R. Education and QA: a model for continuous improvement in skin integrity. J Nurs Qual Assur 1990 Nov;5(1):1-7.
Aronoff GR, Friedman SJ, Doedens DJ, Lavelle KJ. Increased serum iodide concentration from iodine absorption through wounds treated topically with povidone-iodine. Am J Med Sci 1980 May-Jun;279(3):173-6.
Arregui J, Canon B, Murray JE, O'Leary JJ Jr. Long-term evaluation of ischiectomy in the treatment of pressure ulcers. Plast Reconstr Surg 1965 Dec;36(6):583-90.
Aust JB, Page CP. Hemicorporectomy. J Surg Oncol 1985 Dec;30(4):226-30.
Baek SM, Williams GD, McElhinney AJ, Simon BE. The gluteus maximus myocutaneous flap in the management of pressure sores. Ann Plast Surg 1980 Dec;5(6):471-6.
Bailey BN. Surgical closure of sacral sores. Proc R Soc Med 1971 Nov;64(11):1148.
Bale S, Harding KG. Using modern dressings to effect debridement. Prof Nurse 1990;5(5):244-5.
Baranoski S. Collaborative roles lead to success in wound healing. Decubitus 1992 May;5(3):66-8.
Barbenel JC, Jordan MM, Nicol SM, Clark MO. Incidence of pressure-sores in the Greater Glasgow Health Board area. Lancet 1977 Sep 10;2(8037):548-50.
Barnes SH. Patient/family education for the patient with a pressure necrosis. Nurs Clin North Am 1987 Jun;22(2):463-74.
Baron M, Skrinskas G, Urowitz MB, Madras PN. Prostaglandin E1 therapy for digital ulcers in scleroderma. Can Med Assoc J 1982 Jan 1;126(1):42-5.
Barrett D Jr, Klibanski A. Collagenase debridement. Am J Nurs 1973 May;73(5):849-51.
Bates-Jensen B. New pressure ulcer status tool. Decubitus 1990 Aug;3(3):14-5.
Becker H. The distally-based gluteus maximus muscle flap. Plast Reconstr Surg 1979 May;63(5):653-6.
Beltran KA, Thacker JG, Rodeheaver GT. Impact pressures generated by commercial wound irrigation devices. (Unpublished research report). Charlottesville (VA): University of Virginia Health Science Center; 1994.
Bendy RH Jr, Nuccio PA, Wolfe E, Collins B, Tamburro C, Glass W, Martin CM. Relationship of quantitative wound bacterial counts to healing of decubiti: effect of topical gentamicin. Antimicrob Agents Chemother 1964;4:147-55.
Bergevin P, Morris D, Smith RM. Adult education procedures: a handbook of tested patterns for effective participation. New York: Seabury Press; 1963.
Bergstrom N, Braden B. A prospective study of pressure sore risk among institutionalized elderly. J Am Geriatr Soc 1992 Aug;40(8):747-58.
Bergstrom N, Demuth PJ, Braden BJ. A clinical trial of the Braden Scale for Predicting Pressure Sore Risk. Nurs Clin North Am 1987 Jun;22(2):417-28.
Berkwits L, Yarkony GM, Lewis V. Marjolin's ulcer complicating a pressure ulcer: case report and literature review. Arch Phys Med Rehabil 1986 Nov;67(11):831-3.
Berlowitz DR, Wilking SV. Risk factors for pressure sores: a comparison of cross-sectional and cohort-derived data. J Am Geriatr Soc 1989 Nov;37(11):1043-50.
Berlowitz DR, Wilking SV. The short-term outcome of pressure sores. J Am Geriatr Soc 1990 Jul;38(7):748-52.
Bhaskar SN, Cutright DE, Gross A. Effect of water lavage on infected wounds in the rat. J Periodontol 1969 Nov;40(11):671-2.
Bih LI, Lu SY. The rehabilitation of pressure sores after myocutaneous flap surgery. Taiwan I Hsueh Hui Tsa Chih 1989 Apr;88(4):387-93.
Black JM, Black SB. Surgical management of pressure ulcers. Nurs Clin North Am 1987 Jun;22(2):429-38.
Blom MF. Dramatic decrease in decubitus ulcers. Geriatr Nurs (New York) 1985 Mar-Apr;6(2):84-7.
Bodnar B, Myron P. Portrait of practice: reducing the prevalence of pressure ulcers. Decubitus 1992 Mar;5(2):49-52.
Bohannon RW. Whirlpool versus whirlpool rinse for removal of bacteria from a venous stasis ulcer. Phys Ther 1982 Mar;62(3):304-8.
Bolton L, van Rijswijk L. Wound dressings: meeting clinical and biological needs. Dermatol Nurs 1991 Jun;3(3):146-61.
Bovet JL, Nassif TM, Guimberteau JC, Baudet J. The vastus lateralis musculocutaneous flap in the repair of trochanteric pressure sores: technique and indications. Plast Reconstr Surg 1982 May;69(5):830-4.
Boxer AM, Gottesman N, Bernstein H, Mandl I. Debridement of dermal ulcers and decubiti with collagenase. Geriatrics 1969 Jul;24(7):75-86.
Braddom RL, Leadbetter MG. The use of a tissue expander to enlarge a graft for surgical treatment of a pressure ulcer in a quadriplegic: case report. Am J Phys Med Rehabil 1989 Apr;68(2):70-2.
Braden BJ, Bryant R. Innovations to prevent and treat pressure ulcers. Geriatr Nurs 1990 Jul-Aug;11(4):182-6.
Brand PW. Pressure sores—the problem. In: Kenedi RM, Cowden JM, Scales JT, editors. Bed sore biomechanics. London: Macmillan; 1976. p. 19-23.
Brandeis GH, Morris JN, Nash DJ, Lipsitz LA. The epidemiology and natural history of pressure ulcers in elderly nursing home residents. JAMA 1990 Dec 12;264(22):2905-9. [See Comment in: JAMA 1991 Apr 3:265(13):1688.].
Breslow RA, Hallfrisch J, Goldberg AP. Malnutrition in tubefed nursing home patients with pressure sores. J Parenter Enteral Nutr 1991 Nov-Dec;15(6):663-8.
Breslow RA, Hallfrisch J, Guy DG, Crawley B, Goldberg AP. The importance of dietary protein in healing pressure ulcers. J Am Geriatr Soc 1993 Apr;41(4):357-62.
Brewer DJ. Skin care chart development. Ostomy Wound Manage 1989 Spring;22:53-5.
Brown LL, Shelton HT, Bornside GH, Cohn I Jr. Evaluation of wound irrigation by pulsatile jet and conventional methods. Ann Surg 1978 Feb;187(2):170-3.
Bruck JC, Buttemeyer R, Grabosch A, Gruhl L. More arguments in favor of myocutaneous flaps for the treatment of pelvic pressure sores. Ann Plast Surg 1991 Jan;26(1):85-8.
Bryan CS, Dew CE, Reynolds KL. Bacteremia associated with decubitus ulcers. Arch Intern Med 1983 Nov;143(11):2093-5.
Bryant CA, Rodeheaver GT, Reem EM, Nichter LS, Kenney JG, Edlich RF. Search for a nontoxic surgical scrub solution for periorbital lacerations. Ann Emerg Med 1984 May;13(5):317-21.
Burkey JL, Weinberg C, Brenden RA. Differential methodologies for the evaluation of skin and wound cleansers. Wounds 1993;5(6):284-91.
Burkhardt BR. An alternative to the total-thigh flap for coverage of massive decubitus ulcers. Plast Reconstr Surg 1972 Apr;49(4):433-8.
Burr RG. Blood zinc in the spinal patient. J Clin Pathol 1973 Oct;26(10):773-5.
Bush CA. Study of pressures on skin under ischial tuberosities and thighs during sitting. Arch Phys Med Rehabil 1969 Apr;50(4):207-13.
Byrne N, Feld M. Overcoming the red menace: preventing and treating decubitus ulcers. Nursing 1984 Apr;14(4):55-7.
Carley PJ, Wainapel SF. Electrotherapy for acceleration of wound healing: low intensity direct current. Arch Phys Med Rehabil 1985 Jul;66(7):443-6.
Carr RD, Lalagos DE. Clinical evaluation of a polymeric membrane dressing in the treatment of pressure ulcers. Decubitus 1990 Aug;3(3):38-42.
Center for Disease Control (CDC). Isolation techniques for use in hospitals. Atlanta (GA): Center for Disease Control; 1970. Public Health Service Publication No. 2054.
Chen HC, Weng CJ, Noordhoff MS. Coverage of multiple extensive pressure sores with a single filleted lower leg myocutaneous free flap. Plast Reconstr Surg 1986 Sep;78(3):396-8.
Chen LH, Fan-Chiang WL. Biochemical evaluation of riboflavin and vitamin B6 status of institutionalized and non-institutionalized elderly in central Kentucky. Int J Vitam Nutr Res 1981;51(3):232-8.
Chernoff R, Milton K, Lipschitz D. The effect of a very high-protein liquid formula (Replete) on decubitus ulcer healing in long-term tube-fed institutionalized patients [abstract]. J Am Diet Assoc 1990;90(9):A-130.
Chow AW, Galpin JE, Guze LB. Clindamycin for treatment of sepsis caused by decubitus ulcers. J Infect Dis 1977 Mar;135 Suppl:S65-8.
Clarke M, Kadhom HM. The nursing prevention of pressure sores in hospital and community patients. J Adv Nurs 1988 May;13(3):365-73.
Cochran JH Jr, Edstrom LE, Dibbell DG. Usefulness of the innervated tensor fascia lata flap in paraplegic patients. Ann Plast Surg 1981 Oct;7(4):286-8.
Coleman JJ 3d, Jurkiewicz MJ. Methods of providing sensation to anesthetic areas. Ann Plast Surg 1984 Feb;12(2):177-86.
Colwell JC, Foreman MD, Trotter JP. A comparison of the efficacy and cost-effectiveness of two methods of managing pressure ulcers. Decubitus 1992 Jul;6(4):28-36.
Conine TA, Choi AK, Lim R. The user-friendliness of protective support surfaces in prevention of pressure sores. Rehabil Nurs 1989 Sep-Oct;14(5):261-3.
Conine TA, Daechsel D, Lau MS. The role of alternating air and Silicore overlays in preventing decubitus ulcers. J Rehabil Res 1990;13(1):57-65.
Crewe RA. Problems of rubber ring nursing cushions and a clinical survey of alternative cushions for ill patients. Care Sci Pract 1987 Jun;5(2):9-11.
Cruz Santiago G, Kaminski MV Jr, Palencia Salinas C. Adequacy of vitamin C supplementation in total parenteral nutrition [abstract]. J Parenter Enteral Nutr 1981;5(6).
Custer J, Edlich RF, Prusak M, Madden J, Panek P, Wangensteen OH. Studies in the management of the contaminated wound: V. An assessment of the effectiveness of pHisoHex and Betadine surgical scrub solutions. Am J Surg 1971 May;121:572-5.
Daltrey DC, Rhodes B, Chattwood JG. Investigation into the microbial flora of healing and non-healing decubitus ulcers. J Clin Pathol 1981 Jul;34(7):701-5.
Daniel RK, Faibisoff B. Muscle coverage of pressure points—the role of myocutaneous flaps. Ann Plast Surg 1982 Jun;8(6):446-52.
Daniel RK, Hall EJ, MacLeod MK. Pressure sores: a reappraisal. Ann Plast Surg 1979 Jul;3(1):53-63.
Daniel RK, Terzis JK, Cunningham DM. Sensory skin flaps for coverage of pressure sores in paraplegic patients: a preliminary report. Plast Reconstr Surg 1976 Sep;58(3):317-28.
Dealey C. The size of the pressure-sore problem in a teaching hospital. J Adv Nurs 1991 Jun;16(6):663-70.
DeLateur BJ, Berni R, Hangladarom T, Giaconi R. Wheelchair cushions designed to prevent pressure sores: an evaluation. Arch Phys Med Rehabil 1976 Mar;57(3):129-35.
Disa JJ, Carlton JM, Goldberg MH. Efficacy of operative cure in pressure sore patients. Plast Reconstr Surg 1992 Feb;89(2):272-8.
Distel L. More than chart review: a new problem-oriented nursing quality assurance program. QRB Qual Rev Bull 1981 Jan;7(1):26-9.
Dobrzanski S, Kelly CM, Gray JI, Gregg AJ, Cosgrove CA. Granuflex dressings in treatment of full thickness pressure sores. Prof Nurse 1990 Aug;5(11):594-9.
Doughty D, Fairchild P, Stogis S. Your patient: which therapy? J Enterostomal Ther 1990 Jul-Aug;17(4):154-9.
Droessler D, Maibusch RM. Development of a nursing care plan for healing and preventing decubiti. QRB Qual Rev Bull 1979 Aug;5(8):10-14.
Drummond D, Breed AL, Narechania R. Relationship of spine deformity and pelvic obliquity on sitting pressure distributions and decubitus ulceration. J Pediatr Orthop 1985 JulAug;5(4):396-402.
Drummond DS, Narechania RG, Rosenthal AN, Breed AL, Lange TA, Drummond DK. A study of pressure distributions measured during balanced and unbalanced sitting. J Bone Joint Surg Am 1982 Sep;64(7):1034-9.
Ek AC, Boman G. A descriptive study of pressure sores: the prevalence of pressure sores and the characteristics of patients. J Adv Nurs 1982 Jan;7(1):51-7.
Ek AC, Unosson M, Bjurulf P. The modified Norton Scale and the nutritional state. Scand J Caring Sci 1989;3(4):183-7.
El Zayat SG. Preliminary experience with topical phenytoin in wound healing in a war zone. Mil Med 1989 Apr;154(4):178-80.
Engstrand JL. A nursing challenge: effective patient education. AORN J 1979 SepOct;4(5):15-8.
Environmental Protection Agency. Disposal tips for home health care. Washington (DC): U.S. Government Printing Office; 1993 Nov. Report No. EPA530-F-93-027 A. 8 p. Available from: RCRA Docket (5305), U.S. Environmental Protection Agency, 401 M Street, SW, Washington, DC 20460.
Esposito G, Di Caprio G, Ziccardi P, Scuderi N. Tissue expansion in the treatment of pressure ulcers. Plast Reconstr Surg 1991;87(3):501-8. [See Comments in: Plast Reconstr Surg 1991 Dec;88(6):1108, 1116.].
Feedar JA, Kloth LC. Conservative management of chronic wounds. In: Kloth LC, McCulloch JM, Feedar JA, editors. Wound healing: alternatives in management. Philadelphia: FA Davis; 1990.
Feedar JA, Kloth LC, Gentzkow GD. Chronic dermal ulcer healing enhanced with monophasic pulsed electrical stimulation. Phys Ther 1991 Sep;71(9):639-49.
Ferguson-Pell M, Cochran GV, Cardi M, Trachtman L. A knowledge-based program for pressure sore prevention. Ann N Y Acad Sci 1986;463:284-6.
Ferrell BA, Osterweil D, Christenson P. A randomized trial of low-air-loss beds for treatment of pressure ulcers. JAMA 1993 Jan 27;269(4):494-7.
Fincham JE. Smoking cessation: treatment options and the pharmacist's role. Am Pharm 1992 May;NS32(5):62-70.
Firooznia H, Rafii M, Golimbu C, Sokolow J. Computed tomography of pressure sores. J Comput Assist Tomogr 1983a Nov;7(4):367-73.
Firooznia H, Rafii M, Golimbu C, Sokolow J. Computerized tomography in diagnosis of pelvic abscess in spinal-cord-injured patients. Comput Radiol 1983b Nov-Dec;7(6):335-41.
Fisher BH. Topical hyperbaric oxygen treatment of pressure sores and skin ulcers. Lancet 1969;2:405-9.
Fisher J, Arnold PG, Waldorf J, Woods JE. The gluteus maximus musculocutaneous V-Y advancement flap for large sacral defects. Ann Plast Surg 1983 Dec;11(6):517-22.
Fleming A. The action of chemical and physiological antiseptics in a septic wound. Br J Surg 1919;7:99-129.
Foresman PA, Payne DS, Becker D, Lewis D, Rodeheaver GT. A relative toxicity index for wound cleansers. Wounds 1993;5(5):226-31.
Fowler E, Goupil DL. Comparison of the wet-to-dry dressing and a copolymer starch in the management of debrided pressure sores. J Enterostomal Ther 1984 Jan-Feb;11(1):22-5.
French ET, Ledwell-Sifner K. A method for consistent documentation of pressure sores. Rehabil Nurs 1991 Jul-Aug;16(4):204-7.
Freytes HA, Fernandez B, Fleming WC. Ultraviolet light in the treatment of indolent ulcers. South Med J 1965;58:223-6.
Fuhrer MJ, Rintala DH, Hart KA, Clearman R, Young ME. Depressive symptomatology in persons with spinal cord injury who resided in the community. Arch Phys Med Rehabil 1993 Mar;74(3):255-60.
Galpin JE, Chow AW, Bayer AS, Guze LB. Sepsis associated with decubitus ulcers. Am J Med 1976 Sep;61(3):346-50.
Garber SL, Krouskop TA, Carter RE. A system for clinically evaluating wheelchair pressure-relief cushions. Am J Occup Ther 1978 Oct;32(9):565-70.
Garner JS, Favero MS. CDC guidelines for the prevention and control of nosocomial infections: guideline for handwashing and hospital environmental control, 1985. Am J Infect Cont 1986 Jun;14(3):110-29.
Garner JS, Jarvis WR, Emori TG, Horan TC, Hughes JM. CDC definitions for nosocomial infections, 1988. Am J Infect Control 1988 Jun;16(3):128-40. [See Erratum in: Am J Infect Control 1988 Aug;16(4):177.].
Gentzkow GD, Pollack SV, Kloth LC, Stubbs HA. Improved healing of pressure ulcers using dermapulse, a new electrical stimulation device. Wounds 1991 Sep-Oct;3(5):158-70.
Ger R, Levine SA. The management of decubitus ulcers by muscle transposition: an 8-year review. Plast Reconstr Surg 1976 Oct;58(4):419-28.
Gerson LW. The incidence of pressure sores in active treatment hospitals. Int J Nurs Stud 1975;12(4):201-4.
Goren D. Use of Omiderm in treatment of low-degree pressure sores in terminally ill cancer patients. Cancer Nurs 1989 Jun;12(3):165-9.
Gorse GJ, Messner RL. Improved pressure sore healing with hydrocolloid dressings. Arch Dermatol 1987 Jun;123(6):766-71.
Gosnell DJ, Pontius C. A model of quality assurance for decubitus ulcer monitoring. Decubitus 1988 Nov;1(4):24-9.
Gould D. Pressure for change. Nurs Mirror 1985 Oct 16;161(16):28-30.
Gould D. Pressure sore prevention and treatment: an example of nurses' failure to implement research findings. J Adv Nurs 1986 Jul;11(4):389-94.
Gray BC, Salzberg CA, Petro JA, Salisbury RE. The expanded myocutaneous flap for reconstruction of the difficult pressure sore. Decubitus 1990 May;3(2):17-20.
Green E, Katz J. Practice guidelines for management of pressure ulcers. Decubitus 1991 Feb;4(1):36, 38, 40, 42.
Green VA, Carlson HC, Briggs RL, Stewart JL. A comparison of the efficacy of pulsed mechanical lavage with that of rubber-bulb syringe irrigation in removal of debris from avulsive wounds. Oral Surg Oral Med Oral Pathol 1971 Jul;32(1):158-64.
Griffin JW, Tooms RE, Mendius RA, Clifft JK, Vander Zwaag R, El-Zeky F. Efficacy of high voltage pulsed current for healing of pressure ulcers in patients with spinal cord injury. Phys Ther 1991 Jun;71(6):433-42.
Gross A, Cutright DE, Bhaskar SN. Effectiveness of pulsating water jet lavage in treatment of contaminated crushed wounds. Am J Surg 1972 Sep;124(3):373-7.
Gruber RP, Heitkamp DH, Billy LJ, Amato JJ, Arsenal E. Skin permeability of oxygen and hyperbaric oxygen. Arch Surg 1970;101:69-70.
Hackler RH, Zampieri TA. Urethral complications following ischiectomy in spinal cord injury patients: a urethral pressure study. J Urol 1987 Feb;137(2):253-5.
Haher JN, Haher TR, Devlin VJ, Schwartz J. The release of flexion contractures as a prerequisite for the treatment of pressure sores in multiple sclerosis: a report of ten cases. Ann Plast Surg 1983 Sep;11(3):246-9.
Hall PA, Young JV. Autonomic hyperreflexia in spinal cord injured patients: trigger mechanism—dressing changes of pressure sores. J Trauma 1983 Dec;23(12):1074-5.
Haller KB, Reynolds MA, Horsley JA. Developing research-based innovation protocols: process, criteria, and issues. Res Nurs Health 1979 Jun;2(2):45-51.
Hamer ML, Robson MC, Krizek TJ, Southwick WO. Quantitative bacterial analysis of comparative wound irrigations. Ann Surg 1975 Jun;181(6):819-22.
Hamilton L, Quek P, Lew N, Li K, Topp R. Pressure ulcers: an interdisciplinary protocol for prevention and treatment. Perspectives 1989 Spring;13(1):9-15.
Hanan K, Scheele L. Albumin vs. weight as a predictor of nutritional status and pressure ulcer development. Ostomy Wound Manage 1991 Mar-Apr;33(2):22-7.
Hentz VR. Management of pressure sores in a specialty center: a reappraisal. Plast Reconstr Surg 1979 Nov;64(5):683-91.
Hentzen B, Bergstrom N, Pozehl B. Prevalence and incidence of pressure ulcers and associated risk factors in a rural-based home health population. Poster presented at: 17th Annual Midwest Nursing Research Society; 1993 Mar 28-30; Cleveland, OH.
Herceg SJ, Harding RL. Surgical treatment of pressure sores. Arch Phys Med Rehabil 1978 Apr;59(4):193-200.
Heywood AJ, Quaba AA. Modified gluteus maximus V-Y advancement flaps. Br J Plast Surg 1989 May;42(3):263-5.
Hill HL, Brown RG, Jurkiewicz MJ. The transverse lumbosacral back flap. Plast Reconstr Surg 1978;62:177-84.
Hobson DA. Comparative effects of posture on pressure and shear at the body seat interface. J Rehabil Res Dev 1992 Fall;29(4):21-31.
Holman PD. Preservation of the lower extremity in the treatment of massive pressure ulcers. Ariz Med 1985 Feb;42(2):93-9.
Holmes R, Macchiano K, Jhangiani SS, Agarwal NR, Savino JA. Nutrition know-how: combating pressure sores—nutritionally. Am J Nurs 1987 Oct;87(10):1301-3.
Hooker EZ, Sibley P, Nemchausky B, Lopez E. A method for quantifying the area of closed pressure sores by sinography and digitometry. J Neurosci Nurs 1988 Apr;20(2):118-27.
International Association of Enterostomal Therapy. Dermal wounds: pressure sores. Philosophy of the IAET. J Enterostomal Ther 1988 Jan-Feb;15(1):4-17.
Irvine A, Black C. Pressure sore practices. Nurs Times 1990 Sep 19-25;86(38):74-8.
Iverson-Carpenter MS. Focus: nursing diagnosis. Impaired skin integrity. J Gerontol Nurs 1988 Mar;14(3):25-9.
Jackson BS, Chagares R, Nee N, Freeman K. The effects of the Clinitron Bed on pressure ulcers: an experimental study. (Unpublished research report). New York: The Moses Division, Montefiore Medical Center; 1986.
Jackson BS, Chagares R, Nee N, Freeman K. The effects of a therapeutic bed on pressure ulcers: an experimental study. J Enterostomal Ther 1988 Nov-Dec;15(6):220-6.
Jensen TT, Juncker Y. Pressure sores common after hip operations. Acta Orthop Scand 1987 Jun;58(3):209-11.
Johnson AR, White AC, McAnalley B. Comparison of common topical agents for wound treatment: cytotoxicity for human fibroblasts in culture. Wounds 1989 Nov;1(3):186-92.
Johnson CA. Hearing loss following the application of topical neomycin. J Burn Care Rehabil 1988 Mar-Apr;9(2):162-4.
Jones FA. Annual oration on peptic ulcer—in perspective. Trans Med Soc Lond 1985-86;102:101-12.
Jones RC, Shires GT. Principles in the management of wounds. In: Schwartz SI, editor. Principles of surgery. New York: McGraw-Hill; 1974. p. 204.
Kahn J. Case reports: open wound management with the HeNe (6328AU) cold laser. J Orthop Sports Phys Ther 1984;6(3):203-4.
Kaminski MV Jr. Enteral hyperalimentation. Surg Gynecol Obstet 1976 Jul;143(1):12-6.
Karaca AR, Binns JH, Blumenthal FS. Complications of total ischiectomy for the treatment of ischial pressure sores. Plast Reconstr Surg 1978 Jul;62(1):96-9.
Kemp MG, Krouskop TA. Pressure ulcers: reducing the incidence and severity by managing pressure. J Gerontol Nurs 1994;20(9):27-34.
King RB, French ET. Procedures to maintain and restore tissue integrity. In: Rehabilitation Institute of Chicago, Division of Nursing. Rehabilitation nursing procedures manual. Rockville (MD): Aspen; 1990. p. 179-222.
Klein NE, Moore T, Capen D, Green S. Sepsis of the hip in paraplegic patients. J Bone Joint Surg [Am] 1988 Jul;70(6):839-43.
Kloth LC, Feedar JA. Acceleration of wound healing with high voltage, monophasic, pulsed current. Phys Ther 1988 Apr;68(4):503-8. [See Erratum in: Phys Ther 1989 Aug;69(8):702.].
Koshima I, Moriguchi T, Soeda S, Kawata S, Ohta S, Ikeda A. The gluteal perforator-based flap for repair of sacral pressure sores. Plast Reconstr Surg 1993 Apr;91(4):678-83.
Kosiak M. Etiology and pathology of ischemic ulcers. Arch Phys Med Rehabil 1959 Feb;40:62-9.
Krizek TJ, Robson MC. Biology of surgical infection. Surg Clin North Am 1975 Dec;55(6):1261-7.
Kroll SS, Rosenfield L. Perforator-based flaps for low posterior midline defects. Plast Reconstr Surg 1988 Apr;81(4):561-6.
Krouskop TA, Noble PC, Garber SL, Spencer WA. The effectiveness of preventive management in reducing the occurrence of pressure sores. J Rehabil Res Dev 1983 Jul;20(1):74-83.
Krupp S, Kuhn W, Zaech GA. The use of innervated flaps for the closure of ischial pressure sores. Paraplegia 1983 Apr;21(2):119-26.
Kucan JO, Robson MC, Heggers JP, Ko F. Comparison of silver sulfadiazine, povidone-iodine and physiologic saline in the treatment of chronic pressure ulcers. J Am Geriatr Soc 1981 May;29(5):232-5.
Kurzuk-Howard G, Simpson L, Palmieri A. Decubitus ulcer care: a comparative study. West J Nurs Res 1985 Feb;7(1):58-79.
LaMantia JG, Hirschwald JF, Goodman CL, Wooden VM, Delisser O, Staas WE. A program design to reduce chronic readmissions for pressure sores. Rehabil Nurs 1987 Jan-Feb;12(1):22-5.
Langemo DK, Olson B, Hunter S, Burd C, Hansen D, Cathcart-Silberberg T. Incidence of pressure sores in acute care, rehabilitation, extended care, home health, and hospice in one locale. Decubitus 1989 May;2(2):42.
Langemo DK, Olson B, Hunter S, Hansen D, Burd C, Cathcart-Silberberg T. Incidence and prediction of pressure sores in five patient care settings. Decubitus 1991 Aug;4(3):25-6, 28, 30 passim.
Law D. A guide to pressure ulcer prevention care. 1990. Available from: Span America Medical Systems, Inc., Greenville, SC.
Lawton RL, De Pinto V. Bilateral hip disarticulation in paraplegics with decubitus ulcers. Arch Surg 1987 Sep;122(9):1040-3.
Lazarus G, Cooper D, Knighton D, Margolis D, Pecoraro R, Rodeheaver G, Robson M. Definitions and guidelines for assessment of wounds and evaluation of healing. Paper commissioned by the Wound Healing Society, 1992. (Financial support provided by Marion Merrill Dow and Johnson & Johnson). Available from: Wound Healing Society, Richmond, VA.
Lee LK, Ambrus JL. Collagenase therapy for decubitus ulcers. Geriatrics 1975 May;30(5):91-3, 97-8.
Lewis VL Jr. Tensor fasciae latae VY retroposition flap [letter]. Plast Reconstr Surg 1989 Dec;84(6):1016-7.
Lewis VL Jr, Bailey MH, Pulawski G, Kind G, Bashioum RW, Hendrix RW. The diagnosis of osteomyelitis in patients with pressure sores. Plast Reconstr Surg 1988 Feb;81(2):229-32.
Lewis VL Jr, Cunningham BL, Hugo NE. Tensor fasciae latae VY retroposition flap. Ann Plast Surg 1981 Jan;6(1):34-7.
Leyden JJ. Corn starch, Candida albicans, and diaper rash. Pediatr Dermatol 1984 Apr;1(4):322-5.
Leyden JJ, Katz S, Stewart R, Kligman AM. Urinary ammonia and ammonia-producing microorganisms in infants with and without diaper dermatitis. Arch Dermatol 1977 Dec;113(12):1678-80.
Lindan O. Etiology of decubitus ulcers: an experimental study. Arch Phys Med Rehabil 1961 Nov;42(11):774-83.
Lineaweaver W, Howard R, Soucy D, McMorris S, Freeman J, Crain C, Robertson J, Rumley T. Topical antimicrobial toxicity. Arch Surg 1985 Mar;120(3):267-70.
Lingner C, Rolstad BS, Wetherill K, Danielson S. Clinical trial of a moisture vapor-permeable dressing on superficial pressure sores. J Enterostomal Ther 1984 Jul-Aug;11(4):147-9.
Longe RL. Current concepts in clinical therapeutics: pressure sores. Clin Pharm 1986 Aug;5(8):669-81.
Longmire AW, Broom LA, Burch J. Wound infection following high-pressure syringe and needle irrigation [letter]. Am J Emerg Med 1987 Mar;5(2):179-81.
Lubin BS, Powell T. Pressure sores and specialty beds: cost containment and ensurance of quality care. J ET Nurs 1991 Nov-Dec;18(6):190-7.
Luscher NJ, de Roche R, Krupp S, Kuhn W, Zach GA. The sensory tensor fasciae latae flap: a 9-year follow-up. Ann Plast Surg 1991 Apr;26(4):306-10, 311.
Lydon MJ, Hutchinson JJ, Rippon M, Johnson E, de Sousa N, Scudder C, Ryan TJ, Cherry GW. Dissolution of wound coagulum and promotion of granulation tissue under DuoDERM. Wounds 1989 Aug;1(2):95-106.
Lyman IR, Tenery JH, Basson RP. Correlation between decrease in bacterial load and rate of wound healing. Surg Gynecol Obstet 1970 Apr;130(4):616-21.
Lynch P, Cummings MJ, Roberts PL, Herriott MJ, Yates B, Stamm WE. Implementing and evaluating a system of generic infection precautions: body substance isolation. Am J Infect Control 1990 Feb;18(1):1-12.
Lynch P, Jackson MM, Cummings MJ, Stamm WE. Rethinking the role of isolation practices in the prevention of nosocomial infections. Ann Intern Med 1987 Aug;107(2):243-6.
MacKinnon JL, Cleek PJ. The penetration of ultraviolet light through transparent dressings: a case report. Phys Ther 1984 Feb;64(2):204.
Maklebust J, Magnan MA. Approaches to patient and family education for pressure ulcer management. Decubitus 1992 Jul;5(7):18-20, 24, 26.
Maklebust J, Sieggreen M. Pressure ulcers: guidelines for prevention and nursing management. West Dundee (IL): S-N Publications, 1991. 212 p.
Mandrekas AD, Mastorakos DP. The management of decubitus ulcers by musculocutaneous flaps: a five-year experience. Ann Plast Surg 1992 Feb;28(2):167-74.
Maruyama Y, Hamano Y. Sartorius musculocutaneous flap in the repair of trochanteric pressure sore. Keio J Med 1978 Oct;27(2):63-7.
Maruyama Y, Ohnishi K, Takeuchi S. The lateral thigh fascio-cutaneous flap in the repair of ischial and trochanteric defects. Br J Plast Surg 1984 Jan;37(1):103-7.
Mathes SJ, Feng LJ, Hunt TK. Coverage of the infected wound. Ann Surg 1983 Oct;198(4):420-9.
McDiarmid T, Burns PN, Lewith GT, Machin D. Ultrasound and the treatment of pressure sores. Physiotherapy 1985;71(2):66-70.
McGregor JC, Buchan AC. Our clinical experience with the tensor fasciae latae myocutaneous flap. Br J Plast Surg 1980 Apr;33(2):270-6.
Meehan M. Multisite pressure ulcer prevalence survey. Decubitus 1990 Nov;3(4):14-7.
Melcher RE, Longe RL, Gelbart AO. Pressure sores in the elderly: a systematic approach to management. Postgrad Med 1988 Jan;83(1):299-308.
Merbitz CT, King RB, Bleiberg J, Grip JC. Wheelchair push-ups: measuring pressure relief frequency. Arch Phys Med Rehabil 1985 Jul;66(7):433-8.
Mester E, Mester AF, Mester A. The biomedical effects of laser application. Lasers Surg Med 1985;5(1):31-9.
Micali G, Romeo L. Experience with trapezius and tensor fascia lata myocutaneous flaps. Ann Plast Surg 1982 Aug;9(2):94-100.
Michocki RJ, Lamy PP. The care of decubitus ulcers pressure sores. J Am Geriatr Soc 1976 May;24(5):217-24.
Miller H, Delozier J. Cost implications of the pressure ulcer treatment guideline. Columbia (MD): Center for Health Policy Studies; 1994. Contract No. 282-91-0070. 17 p. Sponsored by the Agency for Health Care Policy and Research.
Miller TV, Rantz M. Quality assurance—guaranteeing a high level of care. J Gerontol Nurs 1989 Nov;15(11):10-5.
Minami RT, Hentz VR, Vistnes LM. Use of vastus lateralis muscle flap for repair of trochanteric pressure sores. Plast Reconstr Surg 1977 Sep;60(3):364-8.
Minami RT, Mills R, Pardoe R. Gluteus maximus myocutaneous flaps for repair of pressure sores. Plast Reconstr Surg 1977 Aug;60(2):242-9.
Moody BL, Fanale JE, Thompson M, Vaillancourt D, Symonds G, Bonasoro C. Impact of staff education on pressure sore development in elderly hospitalized patients. Arch Intern Med 1988 Oct;148(10):2241-3.
Morgan JE. Recurrence of pressure ulcers: a study of five cases. JAMA 1976 Nov 22;236(21):2430-1.
Morison MJ. Pressure sore management: the patient's role. Prof Nurse 1989 Dec;5(3):134, 136, 138 passim.
Motta GJ. The effectiveness of Dermagran topical therapy for treating chronic wounds in nursing facility residents. Ostomy Wound Manage 1991 Sep-Oct;36:35-8.
Muguti GI. Early experience with reconstructive surgery at Mpilo Central Hospital, Zimbabwe. J R Coll Surg Edinb 1990 Aug;35(4):248-51.
Mulder G, Seeley J. The effectiveness of specialty beds in the treatment of severe pressure ulcers in nursing home patients: a preliminary report. (Unpublished research report). Aurora (CO): Wound Healing Institute; 1991.
Mulholland JH, Tui C, Wright AM, Vinci V, Shafiroff B. Protein metabolism and bedsores. Ann Surg 1943;118:1015-23.
Mummery RV, Richardson WW. Clinical trial of Debrisan in superficial ulceration. J Int Med Res 1979;7(4):263-71.
Munro BH, Brown L, Heitman BB. Pressure ulcers: one bed or another? Geriatr Nurs (New York) 1989 Jul-Aug;10(4):190-2.
Nath M, Taylor RG.1978
National Center for Cost Containment. National specialized bed study and other support surface guidelines. Milwaukee (WI): Department of Veterans Affairs; 1992 Feb. Available from: National Center for Cost Containment, 5000 West National Avenue, Milwaukee, WI 53295.
National Pressure Ulcer Advisory Panel (NPUAP). Pressure ulcers prevalence, cost and risk assessment: consensus development conference statement. Decubitus 1989 May;2(2):24-8.
Neiderhuber S, Stribley R, Koepke G. Reduction of skin bacterial load with use of therapeutic whirlpool. Phys Ther 1975;55(5):482-6.
Neill KM, Conforti C, Kedas A, Burris JF. Pressure sore response to a new hydrocolloid dressing. Wounds 1989 Nov;1(3):173-85.
Nimit K. Public Health Service assessment guidelines for home air-fluidized bed therapy. Health Technol Assess Rep 1989;(5):1-11.
Nuseibeh IM. Split skin graft and the treatment of pressure sores. Paraplegia 1974 May;12(1):1-4.
Nutrition screening manual for professionals caring for older Americans: nutrition screening initiative. Washington (DC): Greer, Margolis, Mitchell, Grunwald & Associates; 1991. 24 p. Available from: The Nutrition Screening Initiative, 2626 Pennsylvania Avenue, NW, Suite 301, Washington, DC 20037.
Oleske DM, Smith XP, White P, Pottage J, Donovan MI. A randomized clinical trial of two dressing methods for the treatment of low-grade pressure ulcers. J Enterostomal Ther 1986 May-Jun;13(3):90-8.
Olsson AG. Intravenous prostacyclin for ischemic ulcers in peripheral artery disease [letter]. Lancet 1980 Nov 15;2(8203):1076.
Oot-Giromini B, Bidwell FC, Heller NB, Parks ML, Prebish EM, Wicks P, Williams PM. Pressure ulcer prevention versus treatment, comparative product cost study. Decubitus 1989 Aug;2(3):52-4.
Paletta CE, Freedman B, Shehadi S. The VY tensor fasciae latae musculocutaneous flap. Plast Reconstr Surg 1989 May;83(5):852-7.
Panel for the Prediction and Prevention of Pressure Ulcers in Adults. Pressure ulcers in adults: prediction and prevention. Clinical Practice Guideline, No. 3. Rockville (MD): Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services; 1992 May. AHCPR Publication No. 92-0047. 63 p.
Parish LC, Witkowski JA. Clinitron therapy and the decubitus ulcer: preliminary dermatologic studies. Int J Dermatol 1980 Nov;19(9):517-8.
Park CA. Activity positioning and ischial tuberosity pressure: a pilot study. Am J Occup Ther 1992 Oct;46(10):904-9.
Parkash S, Banerjee S. The total gluteus maximus rotation and other gluteus maximus musculocutaneous flaps in the treatment of pressure ulcers. Br J Plast Surg 1986 Jan;39(1):66-71.
Parry SW, Mathes SJ. Bilateral gluteus maximus myocutaneous advancement flaps: sacral coverage for ambulatory patients. Ann Plast Surg 1982 Jun;8(6):443-5.
Pearlman NW, McShane RH, Jochimsen PR, Shirazi SS. Hemicorporectomy for intractable decubitus ulcers. Arch Surg 1976 Oct;111(10):1139-43.
Peters W, Cartotto R, Morris S, Jewett M. The rectus femoris myocutaneous flap for closure of difficult wounds of the abdomen, groin, and trochanteric area. Ann Plast Surg 1991 Jun;26(6):572-6.
Petersen NC, Bittmann S. The epidemiology of pressure sores. Scand J Plast Reconstr Surg 1971;5(1)62-6.
Phipps M, Bauman B, Berner D, Butler M, Kalinoski A, Looby M, Malacaria N, Pratt L, Reiley P, Sullivan M. Staging care for pressure sores. Am J Nurs 1984 Aug;84(8):999-1003.
Pinchcofsky-Devin GD, Kaminski MV Jr. Correlation of pressure sores and nutritional status. J Am Geriatr Soc 1986;34(6):435-40.
Powell JW. Increasing acuity of nursing home patients and the prevalence of pressure ulcers: a ten year comparison. Decubitus 1989 May;2(2):56-8.
Putnam T, Calenoff L, Betts HB, Rosen JS. Sinography in management of decubitus ulcers. Arch Phys Med Rehabil 1978 May;59(5):243-5.
Rao DB, Sane PG, Georgiev EL. Collagenase in the treatment of dermal and decubitus ulcers. J Am Geriatr Soc 1975 Jan;23(1):22-30.
Read RC. Presidential address: systemic effects of smoking. Am J Surg 1984 Dec;148(6):706-11.
Reddy NP, Cochran GV. Phenomenological theory underlying pressure-time relationship in decubitus ulcer formation [abstract]. Fed Proc 1979 Mar 1;38(3 Pt 2):1153.
Reichel SM. Shearing force as a factor in decubitus ulcers in paraplegics. JAMA 1958 Feb 15;166(7):762-3.
Relander M, Palmer B. Recurrence of surgically treated pressure sores. Scand J Plast Reconstr Surg Hand Surg 1988;22(1):89-92.
Reuler JB, Cooney TG. The pressure sore: pathophysiology and principles of management. Ann Intern Med 1981 May;94(5):661-6.
Richardson RR, Meyer PR Jr. Prevalence and incidence of pressure sores in acute spinal cord injuries. Paraplegia 1981;19(4):235-47.
Robnett MK. The incidence of skin breakdown in a surgical intensive care unit. J Nurs Qual Assur 1986 Nov;1(1):77-81.
Robson M, Phillips LG, Thomason A, Robson LF, Pierce GF. Recombinant human growth factor-bb for the treatment of chronic pressure ulcers. Ann Plast Surg 1992a;29:193-201.
Robson M, Phillips LG, Thomason A, Robson LF, Pierce GF. Platelet-derived factors BB for treatment of chronic pressure ulcers. Lancet 1992b;339:23-5.
Robson MC. Plastic surgery in quantitative bacteriology: its role in the armamentarium of the surgeon. In: Heggers JP, Robson MC, editors. Boca Raton (FL): CRC Press; 1991. p. 71-84.
Robson MC, Phillips LG, Lawrence WT, Bishop JB, Youngerman JS, Hayward PG, Broemeling LD, Heggers JP. The safety and effect of topically applied recombinant basic fibroblast growth factor on the healing of chronic pressure sores. Ann Surg 1992 Oct;216(4):401-8.
Roche S, Cross S, Burgess I, Pines C, Cayley AC. Cutaneous myiasis in an elderly debilitated patient. Postgrad Med J 1990 Sep;66(779):776-7.
Rodeheaver GT, Kurtz L, Kircher BJ, Edlich RF. Pluronic F-68: a promising new skin wound cleanser. Ann Emerg Med 1980 Nov;9(11):572-6.
Rodeheaver GT, Pettry D, Thacker JG, Edgerton MT, Edlich RF. Wound cleansing by high pressure irrigation. Surg Gynecol Obstet 1975 Sep;141(3):357-62.
Rodeheaver GT, Smith SL, Thacker JG, Edgerton MT, Edlich RF. Mechanical cleansing of contaminated wounds with a surfactant. Am J Surg 1975 Mar;129(3):241-5.
Rosenthal AM, Schurman A. Hyperbaric treatment of pressure sores. Arch Phys Med Rehabil 1971;52:413-3.
Rottkamp B. An experimental nursing study: a behavior modification approach to nursing therapeutics in body position of spinal cord-injured patients. Nurs Res 1976 May-Jun;25(3):181-6.
Rousseau P. Pressure ulcers in an aging society. Wounds 1989 Aug;1(2):135-41.
Royer J, Pickrell K, Georgiade N, Mladick R, Thorne F. Total thigh flaps for extensive decubitus ulcers: a 16 year review of 41 total thigh flaps. Plast Reconstr Surg 1969 Aug;44(2):109-18.
Rubayi S, Cousins S, Valentine WA. Myocutaneous flaps: surgical treatment of severe pressure ulcers. AORN J 1990 Jul;52(1):40-7,50,52-5.
Rubayi S, Pompan D, Garland D. Proximal femoral resection and myocutaneous flap for treatment of pressure ulcers in spinal injury patients. Ann Plast Surg 1991 Aug;27(2):132-8.
Rutala WA. APIC guideline for selection and use of disinfectants. Am J Infect Control 1990 Apr;18(2):99-117.
Rydberg B, Zederfeldt B. Influence of cationic detergents on tensile strength of healing skin wounds in the rat. Acta Chir Scand 1968;134(5):317-20.
Sachs B, Mathews C. Developing a skin care program. Nurs Manage 1990 Aug;21(8):14-5.
Sagi A, Meller Y, Kon M, Rosenberg L, Ben-Yakar Y. Bilateral hip resection for closure of trochanteric pressure sores: case report. Paraplegia 1987 Feb;25(1):39-43.
Salyer J. Wound management in the home: part II. Home Health Nurse 1988 May-Jun;6(3):29-34.
Salzberg CA, Gray BC, Petro JA, Salisbury RE. The perioperative antimicrobial management of pressure ulcers. Decubitus 1990 May;3(2):24-6.
Sanchez S, Eamegdool S, Conway H. Surgical treatment of decubitus ulcers in paraplegics. Plast Reconstr Surg 1969 Jan;43(1):25-8.
Sapico FL, Ginunas VJ, Thornhill-Joynes M, Canawati HN, Capen DA, Klein NE, Khawam S, Montgomerie JZ. Quantitative microbiology of pressure sores in different stages of healing. Diagn Microbiol Infect Dis 1986 May;5(1):31-8.
Saydak SJ. A pilot test of two methods for the treatment of pressure ulcers. J Enterostomal Ther 1990 May-Jun;17(3):139-42.
Schechter JF, Wilkinson RD, Del Carpio J. Anaphylaxis following the use of bacitracin ointment: report of a case and review of the literature. Arch Dermatol 1984 Jul;120(7):909-11.
Scheflan M, Nahai F, Boswick J 3d. Gluteus maximus island musculocutaneous flap for closure of sacral and ischial ulcers. Plast Reconstr Surg 1981 Oct;68(4):533-8.
Schwartz IS, Pervez N. Bacterial endocarditis associated with a permanent transvenous cardiac pacemaker. JAMA 1971 Nov 1;218(5):736-7.
Scott BO. Clinical use of ultraviolet radiation. In: Stillwell GK, editor. Therapeutic electricity and ultraviolet radiation. Baltimore (MD): Williams & Wilkins; 1983. p. 228-62.
Sebern M. Home-team strategies for treating pressure sores. Nursing 1987 Apr;17(4):50-3.
Sebern MD. Pressure ulcer management in home health care: efficacy and cost effectiveness of moisture vapor permeable dressing. Arch Phys Med Rehabil 1986 Oct;67(10):726-9.
Shand JE, McClemont E. Recent advances in the treatment of pressure sores. Paraplegia 1979 Nov;17(4):400-8.
Shannon ML, Skorga P. Pressure ulcer prevalence in two general hospitals. Decubitus 1989 Nov;2(4):38-43.
Shea JD. Pressure sores: classification and management. Clin Orthop 1975 Oct;(112):89-100.
Shetty KR, Duthie EH Jr. Thyrotoxicosis induced by topical iodine application. Arch Intern Med 1990 Nov;150(11):2400-1.
Siddiqui A, Wiedrich T, Lewis V.Mar;30:1-5.
Siegler EL, Lavizzo-Mourey R. Management of stage III pressure ulcers in moderately demented nursing home residents. J Gen Intern Med 1991 Nov-Dec;6(6):507-13.
Simmons B, Trusler M, Roccaforte J, Smith P, Scott R. Infection control for home health. Infect Control Hosp Epidemiol 1990 Jul;11(7):362-70.
Smoot EC 3d. Clinitron bed therapy hazards [letter]. Plast Reconstr Surg 1986 Jan;77(1):165.
Soriano F, Aguado JM, Tornero J, Fernandez-Guerrero ML, Gomez-Garces JL. Bacteroides fragilis meningitis successfully treated with metronidazole after a previous failure with thiamphenicol. J Clin Microbiol 1986 Sep;24(3):472-3.
Spear SL, Kroll SS, Little JW 3d. Bilateral upper-quadrant (intercostal) flaps: the value of protective sensation in preventing pressure sore recurrence. Plast Reconstr Surg 1987 Nov;80(5):734-6.
St. Clair M. Survey of the uses of the Pegasus airwave system in the United Kingdom. J Tissue Viab 1992;2(1):9-16.
Stevenson TR, Thacker JG, Rodeheaver GT, Bacchetta C, Edgerton MT, Edlich RF. Cleansing the traumatic wound by high pressure syringe irrigation. JACEP 1976 Jan;5(1):17-21.
Stillwell GK. Therapeutic heat and cold. In: Krusen FH, editor. Handbook of physical medicine and rehabilitation. 2nd ed. Philadelphia: Saunders; 1971. p. 259-72.
Strauss MJ, Gong J, Gary BD, Kalsbeek WD, Spear S. The cost of home air-fluidized therapy for pressure sores: a randomized controlled trial. J Fam Pract 1991 Jul;33(1):52-9.
Sugarman B. Osteomyelitis in spinal cord injury. Arch Phys Med Rehabil 1984 Mar;65(3):132-4.
Sugarman B. Pressure sores and underlying bone infection. Arch Intern Med 1987 Mar;147(3):553-5.
Sundell B, Pentti A, Langenskiold A. Surgical treatment of pressure ulcers in paraplegics. Acta Orthop Scand 1967;38(4):532-42.
Surinchak JS, Alago ML, Bellamy RF, Stuck BE, Belkin M. Effects of low-level energy lasers on the healing of full-thickness skin defects. Lasers Surg Med 1983;2(3):267-74.
Taylor TV, Rimmer S, Day B, Butcher J, Dymock IW. Ascorbic acid supplementation in the treatment of pressure sores. Lancet 1974 Sep 7;2(7880):544-6.
Teepe RG, Koebrugge EJ, Lowik CW, Petit PL, Bosboom RW, Twiss IM, Boxma H, Vermeer BJ, Ponec M. Cytotoxic effects of topical antimicrobial and antiseptic agents on human keratinocytes in vitro. J Trauma 1993 Jul;35(1):8-19.
Terz JJ, Schaffner MJ, Goodkin R, Beatty JD, Razor B, Weliky A, Shimabukuro C. Translumbar amputation. Cancer 1990 Jun 15;65(12):2668-75.
Tolhurst DE. "Skin and bone": the use of muscle flaps to cover exposed bone. Br J Plast Surg 1980 Jan;33(1):99-114.
Torrance C. Pressure sores: what goes on? Community Outlook 1983 Nov:332-40.
Tudhope M. Management of pressure ulcers with a hydrocolloid occlusive dressing: results in twenty-three patients. J Enterostomal Ther 1984 May-Jun;11(3):102-5.
University Hospital Consortium. Guidelines for the use of pressure relief devices in the treatment and prevention of pressure ulcers. Oak Brook (IL): University Hospital Consortium Technology Advancement Center; 1990. Available from: University Hospital Consortium Technology Advancement Center, 2001 Spring Road, Suite 700, Oak Brook, IL 60521.
US Preventive Services Task Force. Guide to clinical preventive services: an assessment of the effectiveness of 169 interventions. Baltimore (MD): Williams & Wilkins; 1989. 419 p.
van Rijswijk L. Full-thickness pressure ulcers: patient and wound healing characteristics. Decubitus 1993 Jan;6(1):16-21.
Van Ness CV. The implementation of a quality assurance study and program to reduce the incidence of hospital acquired pressure ulcers. J Enterostomal Ther 1989 Mar-Apr;16(2):61-4.
VanEtten NK, Sexton P, Smith R. Development and implementation of a skin care program. Ostomy Wound Manage 1990 Mar-Apr;27:40-54.
Varma AO, Bugatch E, German FM. Debridement of dermal ulcers with collagenase. Surg Gynecol Obstet 1973 Feb;136(2):281-2.
Vasconez LO, Schneider WJ, Jurkiewicz MJ. Pressure sores. Curr Probl Surg 1977 Apr;14(4):1-62.
Verduin JR, Miller HG, Greer CE. Adults teaching adults. Austin (TX): Learning Concepts; 1977.
Versluysen M. Pressure sores in elderly patients: the epidemiology related to hip operations. J Bone Joint Surg Br 1985 Jan;67(1):10-3.
Versluysen M. How elderly patients with femoral fractures develop pressure sores in hospital. Br Med J Clin Res Ed 1986 May 17;292(6531):1311-3.
Vidal J, Sarrias M. An analysis of the diverse factors concerned with the development of pressure sores in spinal cord patients. Paraplegia 1991 May;29(4):261-7.
Vyas SC, Binns JH, Wilson AN. Thoracolumbar-sacral flaps in the treatment of sacral pressure sores. Plast Reconstr Surg 1980 Feb;65(2):159-63.
Wang TN, Lineaweaver WC, Scott T, Feldman R. Internal pudendal pseudoaneurysm complicating an ischial pressure sore. Ann Plast Surg 1987 Oct;19(4):381-3.
Warner DJ. A clinical comparison of two pressure-reducing surfaces in the management of pressure ulcers. Decubitus 1992 May;5(3):52-5, 58-60, 62-4.
Warren VB, editor. A treasury of techniques for teaching adults. Washington (DC): National Association for Public Continuing and Adult Education; 1977.
Westaby S. Wound care. St. Louis (MO): C. V. Mosby Co.; 1987. p. 14.
Wheeler CB, Rodeheaver GT, Thacker JG, Edgerton MT, Edlich RF. Side-effects of high pressure irrigation. Surg Gynecol Obstet 1976 Nov;143(5):775-8.
Wiersema LA, Lueckenotte AG. Determination of the effectiveness of four sleep surfaces in the treatment of stage 2 and 3 pressure sores. (Unpublished research report). St. Louis (MO): Barnes Hospital; Batesville (IN): Hill-Rom; 1992.
Williams C, Lines C, McKay E. Iron and zinc status in multiple sclerosis patients with pressure sores. Eur J Clin Nutr 1988 Apr;42(4):321-8.
Wills EE, Anderson TW, Beattie BL, Scott A. A randomized placebo-controlled trial of ultraviolet light in the treatment of superficial pressure sores. J Am Geriatr Soc 1983;31(3):131-3.
Xakellis GC, Chrischilles EA. Hydrocolloid versus saline gauze dressings in treating pressure ulcers: a cost-effectiveness analysis. Arch Phys Med Rehabil 1992 May;73:463-9.
Yanai A, Bandoh Y, Tsuzuki K. Bilateral gluteal thigh flaps for closure of large defects in the lumbosacral region and perineal region. Plast Reconstr Surg 1991 Oct;88(4):703-6.
Yarkony GM, Kirk PM, Carlson C, Roth EJ, Lovell L, Heinemann A, King R, Lee MY, Betts HB. Classification of pressure ulcers. Arch Dermatol 1990 Sep;126:1218-9.
Young L. Pressure ulcer prevalence and associated patient characteristics in one long-term care facility. Decubitus 1989 May;2(2):52.
Yuan RT. The use of tissue expansion in lower extremity wounds in paraplegic patients. Plast Reconstr Surg 1989 May;83(5):892-5.
Zimmerer RE, Lawson KD, Calvert CJ. The effects of wearing diapers on skin. Pediatr Dermatol 1986 Feb;3(2):95-101.