# Acknowledgments

Many organizations and individuals made significant contributions during the development of this guideline. Although they are too numerous to mention here, the Contributors section, which appears later in this publication, lists individual consultants, peer reviewers, and support staff. This guideline would not have been possible without their collaborative efforts.

All persons, organizations, and agencies with an interest in the pressure ulcer treatment guideline were invited to participate at a public meeting held in Washington, DC, on April 9, 1992, and the panel gratefully acknowledges the valuable input received during that session.

The National Pressure Ulcer Advisory Panel (NPUAP) and the Wound, Ostomy, and Continence Nurses Society (WOCN) are to be commended for their ongoing efforts to improve the prevention and treatment of pressure ulcers. George T. Rodeheaver, PhD, president of the NPUAP, deserves special recognition for his efforts in mobilizing the NPUAP's resources to provide a forum for peer review of the pressure ulcer treatment guideline. Input from participants attending the jointly sponsored NPUAP and WOCN meeting on March 5-6, 1993, was extremely helpful.

Product manufacturers also contributed to the guideline development process. Many companies responded to requests for published and unpublished information regarding the results of product research. The panel appreciates their contributions.

The panel gratefully acknowledges the supportive efforts of Margaret Coopey, MGA, RN, project officer from the Office of the Forum for Quality and Effectiveness in Health Care, AHCPR, and of William N. LeVee (managing editor) and Karen Carp (product manager) from the Center for Research Dissemination and Liaison, AHCPR.

The panel also extends its gratitude and appreciation to the support staff members for their tireless efforts: Janet Cuddigan, PhC, RN, panel manager, research analyst, and scientific writer; Brenda Bergman-Evans, PhD, RNC, research analyst and scientific writer; Joan Ronnenberg, MSN, RN, research analyst; Elizabeth Gavin, panel secretary; Joyce Black, MSN, RN, scientific writer; and Diane Q. Forti, BA, scientific editor.

Heartfelt gratitude is extended to the families of panel members for their patience, support, and understanding. This guideline is dedicated to the patients we are privileged to serve.