# Panel Members

- Nancy Bergstrom, PhD, RN, FAAN
- Panel Chair, 1991-94
- Professor and Interim Associate Dean
- Graduate Nursing Programs University of Nebraska Medical Center
- Omaha, Nebraska
- Specialty: Pressure Ulcer Research
- Richard M. Allman, MD
- Panelist, 1991-92 Consultant, 1992-94
- Associate Professor of Medicine
- Director of the Center for Aging and the Division of Gerontology and Geriatrics
- University of Alabama at Birmingham
- Chief of Geriatrics Section
- Birmingham Department of Veterans Affairs Medical Center
- Birmingham, Alabama
- Specialty: Geriatric Medicine
- Oscar M. Alvarez, PhD
- 1991-92
- Director
- University Wound Healing Clinic
- New Brunswick, New Jersey
- Specialty: Wound Healing
- M. Alisan Bennett, EdD, RN
- 1993-94
- Supervisor and Special Projects Coordinator Nursing Education and Research
- Woodhull Medical and Mental Health Center of the New York City Health and Hospitals Corporation
- Brooklyn, New York
- Specialty: Preservation of Darkly Pigmented Intact Skin
- Carolyn E. Carlson, PhD, RN
- 1991-94
- Professor of Nursing
- Cedarville College
- Cedarville, Ohio
- Associate Director of Nursing and Allied Health for Research and Evaluation
- Division of Nursing and Allied Health, and Department of Research
- Rehabilitation Institute of Chicago
- Chicago, Illinois
- Specialty: Rehabilitation and Psychiatric Nursing
- Rita A. Frantz, PhD, RN, FAAN
- 1991-94
- Associate Professor
- College of Nursing University of Iowa
- Clinical Associate in Nursing
- Iowa Veterans Home
- Iowa City, Iowa
- Specialty: Wound Care
- Susan L. Garber, MA, OTR, FAOTA
- 1991-94
- Assistant Director for Research and Education
- Department of Occupational Therapy
- The Institute for Rehabilitation and Research
- Assistant Professor
- Department of Physical Medicine and Rehabilitation Baylor College of Medicine
- Houston, Texas
- Specialty: Occupational Therapy
- Bettie S. Jackson, EdD, MBA, FAAN
- 1991-94
- Director of Professional Services
- Department of Nursing Moses Division, Montefiore Medical Center
- Bronx, New York
- Associate Research Scientist
- School of Nursing Columbia University
- New York, New York
- Specialty: Administration and Enterostomal Therapy
- Mitchell V. Kaminski, Jr., MD, SC, FACS, FICS, FACN
- 1991-94
- Staff Surgeon
- Thorek Hospital and Medical Center
- Clinical Professor of Surgery
- Chicago Medical School
- University of Health Sciences
- Chicago, Illinois
- Specialty: Surgery and Nutritional Support
- Mildred G. Kemp, PhD, RN, CETN, FAAN
- 1991-94
- Associate Professor
- College of Nursing
- Rush University
- Practitioner/Teacher
- Department of Operating Room and Surgical Nursing
- Rush-Presbyterian-St. Luke's Medical Center
- Chicago, Illinois
- Specialty: Enterostomal Therapy
- Thomas A. Krouskop, PhD
- 1991-92
- Professor
- Department of Physical Medicine and Rehabilitation
- Baylor College of Medicine
- Director of Rehabilitation Engineering
- The Institute for Rehabilitation and Research
- Houston, Texas
- Specialty: Bioengineering
- Victor L. Lewis, Jr., MD, FACS
- 1991-94
- Associate Professor of Clinical Surgery
- Northwestern University Medical School
- Chicago, Illinois
- Specialty: Plastic Surgery
- JoAnn Maklebust, MSN, RN, CS
- 1991-94
- Clinical Nurse Specialist, Wound Care Case Manager, General and Reconstructive Surgery
- Harper Hospital
- Detroit Medical Center
- Detroit, Michigan
- Specialty: Wound Care
- David J. Margolis, MD, FACP
- 1992-94
- Director
- Cutaneous Ulcer Center
- University of Pennsylvania Medical Center
- Assistant Professor
- Department of Dermatology
- School of Medicine
- University of Pennsylvania
- Philadelphia, Pennsylvania
- Specialty: Dermatology
- Elena M. Marvel, MSN, MA, RN
- 1991-94
- State Coordinator
- Health Advocacy Services Program in New Jersey American Association of Retired Persons
- Short Hills, New Jersey
- Specialty: Consumer Advocacy
- Steven I. Reger, PhD, CP
- 1992-94
- Director of Rehabilitation Engineering
- Department of Physical Medicine and Rehabilitation
- Department of Plastic Surgery
- Department of Biomedical Engineering
- The Cleveland Clinic Foundation
- Cleveland, Ohio
- Specialty: Biomedical Engineering
- George T. Rodeheaver, PhD
- Panelist, 1991-92
- Consultant, 1992-94
- Professor and Director
- Plastic Surgery Research
- Health Sciences Center
- University of Virginia
- Charlottesville, Virginia
- Specialty: Wound Management Research
- Richard Salcido, MD, FAAPMR
- 1993-94
- Interim Chairman
- Department of Physical Medicine and Rehabilitation
- Associate
- Department of Biomedical Engineering
- Associate
- Sanders-Brown Center on Aging
- University of Kentucky
- Cardinal Hill Hospital
- Lexington, Kentucky
- Specialty: Physical Medicine and Rehabilitation
- George C. Xakellis, MD
- 1991-94
- Director of Research and Medical Development
- John Deere Health Care Corporation
- Moline, Illinois
- Specialty: Family Medicine
- Gary M. Yarkony, MD, FAAPMR
- 1992-94
- Vice President for Clinical Development
- Schwab Rehabilitation Hospital and Care Network
- Associate Professor of Clinical Physical Medicine and Rehabilitation
- Northwestern University Medical School
- Chicago, Illinois
- Specialty: Physical Medicine and Rehabilitation