# Treatment of Pressure Ulcers Guideline Panel

- Nancy Bergstrom, PhD, RN, FAAN (Chair)
- Richard M. Allman, MD
- Oscar M. Alvarez, PhD
- M. Alisan Bennett, EdD, RN
- Carolyn E. Carlson, PhD, RN
- Rita A. Frantz, PhD, RN, FAAN
- Susan L. Garber, MA, OTR, FAOTA
- Bettie S. Jackson, EdD, MBA, FAAN
- Mitchell V. Kaminski, Jr., MD, SC, FACS, FICS, FACN
- Mildred G. Kemp, PhD, RN, CETN, FAAN
- Thomas A. Krouskop, PhD
- Victor L. Lewis, Jr., MD, FACS
- JoAnn Maklebust, MSN, RN, CS
- David J. Margolis, MD, FACP
- Elena M. Marvel, MSN, MA, RN
- Steven I. Reger, PhD, CP
- George T. Rodeheaver, PhD
- Richard Salcido, MD, FAAPMR
- George C. Xakellis, MD
- Gary M. Yarkony, MD, FAAPMR