# Education and Quality Improvement

Institutions and agencies concerned with health care are responsible for developing and implementing educational programs designed to translate knowledge about pressure ulcers into effective treatment strategies. The goals of such programs are to promote the healing and prevent the deterioration of existing pressure ulcers and to prevent new ones. The goal of quality improvement is to develop and implement a systematic, interdisciplinary, and ongoing quality improvement (QI) program for facilitating comprehensive, consistent care that can be monitored, evaluated, and changed as patient conditions and current knowledge warrant.

## Education

Recommendations for developing and implementing educational programs are provided in the following categories: Prevention and treatment, assessing tissue damage, and monitoring outcomes.

### Prevention and Treatment: A Continuum

Design, develop, and implement educational programs for patients, caregivers, and health care providers that reflect a continuum of care. The program should begin with a structured, comprehensive, and organized approach to prevention and should culminate in effective treatment protocols that promote healing as well as prevent recurrence. (Strength of Evidence = C.)

Education is the means by which current knowledge about pressure ulcers can be translated into effective strategies for prevention and treatment. Clinicians and scientists alike often include the words "prevention" and "treatment" (or "management") in the titles of their published works, indicating that they see these two concepts as inextricably linked (Byrne and Feld, 1984; Droessler and Maibusch, 1979; Gould, 1986). Although only one study has demonstrated that education (of caregivers) alone was responsible for reducing the incidence or severity of pressure ulcers in a group of hospitalized patients (Moody, Fanale, Thompson, et al., 1988), many investigators have incorporated structured educational programs into a total pressure ulcer management program, with skin integrity the desirable outcome of both preventive and treatment efforts (Distel, 1981; Sachs and Mathews, 1990). Some educational programs include extensive protocols for both prevention and treatment of pressure ulcers (Law, 1990), and others advocate practicing or teaching prevention during the treatment phase (Hamilton, Quek, Lew, et al., 1989). Even though developing and implementing programs that address both prevention and treatment of pressure ulcers may prove time-consuming, this two-pronged approach is essential to maintaining skin integrity and preventing recurrent ulcers.

Develop educational programs that target appropriate health care providers, patients, family members, and caregivers. Present information at an appropriate level for the target audience to maximize retention and ensure a carryover into practice. Use principles of adult learning (e.g., explanation, demonstration, questioning, group discussion, drills). (Strength of Evidence = C.)

Information that is presented at an appropriate level for the target audience is more likely to be retained and carried over into practice (Maklebust and Magnan, 1992). Principles of adult learning should be considered when designing educational programs. Specifically, the program should address the learner's needs, interests, background (vocational, educational, cultural), and current knowledge of the material to be presented (Bergevin, Morris, and Smith, 1963; Verduin, Miller, and Greer, 1977). Objectives should be clear because they provide direction for the learner and teacher as well as content for program development. A clear set of objectives will also allow the instruction and learning to be evaluated. Techniques that work especially well with the adult learner include (but are not limited to) explanation, demonstration, questioning, group discussion, drills, and inquiry (Warren, 1977).

Involve the patient and caregiver, when possible, in pressure ulcer treatment and prevention strategies and options. Include information on pain, discomfort, possible outcomes, and duration of treatment, if known. Encourage the patient to actively participate in and comply with decisions regarding pressure ulcer prevention and treatment. (Strength of Evidence = C.)

Studies have shown that compliance is greater and treatment more successful when the patient participates actively in the process of learning (Andberg, Rudolph, and Anderson, 1983; Barnes, 1987; Engstrand, 1979; LaMantia, Hirschwald, Goodman, et al., 1987). It is recommended that, whenever possible, the patient understand the variety, availability, and relevance of treatment options and participate in decisions regarding management of the pressure ulcer. Information on pain, discomfort, possible outcomes, and, if known, duration of treatment should be included (Morison, 1989; Rottkamp, 1976; Sebern, 1987).

Educational programs should identify those responsible for pressure ulcer treatment and describe each person's role. The information presented and the degree of participation expected should be appropriate to the audience. (Strength of Evidence = C.)

These programs should include specific, accurate, and reliable information about pressure ulcer treatment as well as about appropriate educational methods. Nurses are the target audience in most of the works cited in the literature on the subject (Bates-Jensen, 1990; Dealey, 1991; Distel, 1981; Gosnell and Pontius, 1988; Gould, 1985; Green and Katz, 1991; Miller and Rantz, 1989; ). Health care providers from other disciplines would also benefit from such educational programs. The levels of caregiver training, education, and experience in any one facility will vary. The protocols for pressure ulcer treatment must be developed with consideration for the specific group or level of caregiver who will be assigned to carry out the protocols.

### Assessing Tissue Damage

Educational programs should emphasize the need for accurate, consistent, and uniform assessment, description, and documentation of the extent of tissue damage. (Strength of Evidence = C.)

The most frequently cited content area in teaching protocols and educational programs that address the treatment of pressure ulcers is accurate and consistent assessment, description, and documentation of the extent to which tissue is damaged. Accurate staging and description of the pressure ulcer are a prerequisite to development and implementation of appropriate, effective treatment protocols and to effective, ongoing monitoring of tissue healing (Bolton and van Rijswijk, 1991; Hamilton, Quek, Lew, et al., 1989; Phipps, Bauman, Berner, et al., 1984; Sebern, 1987). To provide effective treatment, caregivers must understand clearly the extent of the tissue damage (Brewer, 1989; French and Ledwell-Sifner, 1991; Sachs and Mathews, 1990). Accurate staging of the ulcer is a prerequisite to development and implementation of appropriate, effective treatment protocols.

Include the following information when developing an educational program on the treatment of pressure ulcers (Strength of Evidence = C):

- Etiology and pathology.
- Risk factors.
- Uniform terminology for stages of tissue damage based on specific classification.
- Principles of wound healing.
- Principles of nutritional support with regard to tissue integrity.
- Individualized program of skin care.
- Principles of cleansing and infection control.
- Principles of postoperative care including positioning and support surfaces.
- Principles of prevention to reduce recurrence.
- Product selection (i.e., categories and uses of support surfaces, dressings, topical antibiotics, or other agents).
- Effects or influence of the physical and mechanical environment on the pressure ulcer, and strategies for management.
- Mechanisms for accurate documentation and monitoring of pertinent data, including treatment interventions and healing progress.

The first step in planning treatment is accurate assessment of the wound. As can be seen from the foregoing list, other essential components of an effective educational program include risk factors and risk assessment; uniform terminology and documentation; individualized skin care; principles of wound cleansing and infection control; and categories and uses of dressings, medications, and support surfaces (Andberg, Rudolph, and Anderson, 1983; Arikian, Kingery, Beall, et al., 1990; Barnes, 1987; Bolton and van Rijswijk, 1991; Braden and Bryant, 1990; Droessler and Maibusch, 1979; Irvine and Black, 1990; Iverson-Carpenter, 1988).

Update educational programs on an ongoing and regular basis to integrate new knowledge, techniques, or technologies. (Strength of Evidence = C.)

Educational programs should be ongoing, presented regularly, and updated frequently. New technologies for the treatment of pressure ulcers are being developed constantly, with many new products now being marketed for cleansing, dressing, and debriding these lesions as well as for providing pressure relief. In many cases these products have not undergone rigorous testing, and, therefore, their effectiveness remains unconfirmed. In addition, many clinicians are uninformed or misinformed about the implications of research designed to identify and analyze proposed treatment strategies. A continuing educational effort is essential to ensure that current information is presented and that knowledge has been retained.

### Monitoring Outcomes

Evaluate the effectiveness of an educational program in terms of measurable outcomes: Implementation of guideline recommendations, healing of existing ulcers, reducing the incidence of new or recurrent ulcers, and preventing the deterioration of existing ulcers. (Strength of Evidence = C.)

Evaluation of outcomes should serve as the basis for changing existing practice and improving care. The effectiveness of educational programs designed to teach assessment and treatment techniques must also be evaluated (Andberg, Rudolph, and Anderson, 1983). Therefore, mechanisms for testing both the knowledge gained and the skills mastered should be an integral part of the educational program (Anderson and Andberg, 1980). Periodic followup will enhance the audience's ability to retain information and improve their skills (Arikian, Kingery, Beall, et al., 1990). Improvements in outcomes depend on knowledgeable nurses and other health care providers who will provide care according to a specific, individualized, and documented plan.

Include a structured, comprehensive, and organized educational program as an integral part of quality improvement monitoring. Use information from quality assurance/improvement surveys to identify deficiencies, to evaluate the effectiveness of care, and to determine the need for education and policy changes. Focus inservice training on identified deficiencies. (Strength of Evidence = C.)

QI surveys can be used to obtain information about the effectiveness of nursing care and the need for additional education or policy changes (Van Ness, 1989). If deficiencies are identified, inservice training can focus on those specific areas (Droessler and Maibusch, 1979). Knowledgeable nurses and ongoing updated inservice education and training are essential if measurable improvements are to be achieved (Gosnell and Pontius, 1988; Miller and Rantz, 1989; VanEtten, Sexton, and Smith, 1990). The results of quality improvement monitoring should serve as the basis for changing practice protocols and improving care.

## Quality Improvement

Recommendations follow on QI to facilitate comprehensive, consistent care of pressure ulcers.

Obtain intradepartmental and interdepartmental QI support for pressure ulcer management as a major aspect of care. (Strength of Evidence = C.)

Support within and between departments is essential for a coordinated and comprehensive program. Support must be provided by clinical departments as well as nonclinical ones such as data management, utilization management, medical records, purchasing, pharmacy, and central supply in order to generate and utilize useful information (Baranoski, 1992).

Convene an interdisciplinary committee of interested and knowledgeable persons to address QI in pressure ulcer management. (Strength of Evidence = C.)

The committee may be convened initially to plan for pressure ulcer prevention rather than treatment. Since pressure ulcer management is a multifactorial, multidisciplinary problem, an interdisciplinary team is essential. Team members may include (but not be limited to) the QI coordinator, clinical nurse specialist, administrator, enterostomal therapy nurse, staff nurses, nutritionist, occupational therapist, physical therapist, geriatrician, and physiatrist. Consultants with special expertise, such as dermatologists or plastic surgeons, may be enlisted as needed. Although team members may vary depending on the type of setting, an interdisciplinary team with consultants can be assembled in acute care settings, long-term care facilities, and home care agencies (Arikian, Kingery, Beall, et al., 1990; Gosnell and Pontius, 1988; LaMantia, Hirschwald, Goodman, et al., 1987).

Identify and monitor the occurrence of pressure ulcers to determine their incidence and prevalence. This information will serve as a baseline to the development, implementation, and evaluation of treatment protocols. (Strength of Evidence = C.)

No data are available to suggest realistic or desirable rates of pressure ulcer prevalence and incidence. Current data vary by setting, such as acute care setting, long-term care facility, and home (via home care agencies); they establish the current status but not what might be achieved with the use of a concerted QI process. On the basis of initial data, goals to maintain the current statistics or improve them should be set by individual institutions and agencies (Arikian, Kingery, Beall, et al., 1990; Bodnar and Myron, 1992; Droessler and Maibusch, 1979).

Monitor the incidence and prevalence of pressure ulcers on a regular basis. (Strength of Evidence = C.)

Baseline data are useful only in initially quantifying the magnitude of the pressure ulcer problem. Regular monitoring is essential in order to track and trend the experience and to evaluate prevention and treatment programs that have been implemented. Several elements should be included in the monitoring process. To the extent possible, data should be collected concurrently rather than retrospectively. Sources of data include direct patient assessment, the medical record, and staff interviews.

Quantitative data elements should include total census, number of patients with pressure ulcers, total number of ulcers, number of ulcers by stage, percentage of ulcers that are nosocomial, and site of ulcers on the body.

Qualitative data may be collected and organized using a structure- process-outcome format. Structure is represented by the availability of supplies, equipment, personnel, and financial support. Process is represented by available standards, policies, procedures, and treatment protocols. Process also includes a documentation system that will facilitate consistent care and the evaluation of that care by means of tracking and trending the patient's skin condition and pressure ulcer characteristics (Blom, 1985; Distel, 1981; Droessler and Maibusch, 1979; Gosnell and Pontius, 1988). Outcomes of care can be measured in terms of the incidence and prevalence of pressure ulcers.

Develop, implement, and evaluate educational programs based on the data obtained from QI monitoring. (Strength of Evidence = C.)

The setting, identification of caregivers, pressure ulcer data, and current information will help guide the content of the educational programs. Although caregiver knowledge of pressure ulcer management is one indicator of the effectiveness of the program, other outcomes should also be emphasized. Thus, caregiver implementation of recommended interventions should be evaluated, as well as measurements of pressure ulcer healing, progression, and prevention (Arikian, Kingery, Beall, et al., 1990; Lubin and Powell, 1991).