# Operative Repair of Pressure Ulcers

Operative procedures to repair pressure ulcers include one or more of the following: Direct closure, skin grafting, skin flaps, musculocutaneous flaps, and free flaps. Although more research is needed to develop clear criteria for selecting those individuals most likely to benefit from surgical management, the panel has provided some general criteria. Preoperative patient counseling should include information about the operative procedures available and the anticipated benefits and potential risks of each. Factors that might impair healing should be addressed preoperatively. Vigilant postoperative followup is considered essential to healing and prevention of recurrence.

## Patient Selection

Determine patient need and suitability for operative repair when clean Stage III or Stage IV pressure ulcers do not respond to optimal patient care (as defined in this guideline). Possible candidates are medically stable and adequately nourished and can tolerate operative blood loss and postoperative immobility. Quality of life, patient preferences, treatment goals, risk of recurrence, and expected rehabilitative outcome are additional considerations. (Strength of Evidence = C.)

Surgical repair can be used to provide a skin covering or to establish durable soft-tissue coverage. Flaps containing muscle are effective in managing osteomyelitis because they provide a physiologic barrier to infection, eliminate dead space in the wound, and improve vascularity. Increased vascularity increases local oxygen tension, enhances the delivery of systemic antibiotics, and improves lymphocyte function (Anthony, Huntsman, and Mathes, 1992; Becker, 1979; Bruck, Buttemeyer, Grabosch, et al., 1991).

Operative procedures may last 1 to 3 hours and may result in a blood loss of up to 1,500 mL. Therefore, patients with medical conditions that would be worsened by anesthesia, blood loss, systemic stress, or immobility following surgery are usually not candidates for repair. Adequate nutrition is essential for wound healing. Several laboratory parameters can be used to assist in evaluating the patient's nutritional status, including serum levels of hemoglobin, transferrin, and albumin and lymphocyte counts. See Chapter 2, Assessment, for a complete discussion of nutritional assessment.

Surgical repair of Stage IV ulcers is common because flaps provide more durable tissue than does scar tissue. One decision analysis suggests that surgery would be favored for repair of Stage III ulcers in nursing home residents with moderate dementia unless the rate of operative success was below 30 percent or the projected rate of healing with conservative management was over 40 percent. Although operative repair was $17,000 more costly than conservative treatment, it would improve 1-year survival rates in this population (Siegler and Lavizzo-Mourey, 1991). This cost analysis assumes continued residence at the nursing home. Average healing time was reported to decrease from 12.8 weeks with skin grafts to 4.8 weeks with musculocutaneous flaps (Anthony, Huntsman, and Mathes, 1992).

In contrast, the rate of healing for medically managed Stage III ulcers in nursing home patients was 14 percent at 6 weeks (Berlowitz and Wilking, 1990), 31.5 percent at 3 months, and 58.9 percent at 6 months (Brandeis, Morris, Nash, et al., 1990). Conservative medical management resulted in healed wounds in 23.3 percent of Stage IV pressure ulcers at 3 months and in 33.2 percent at 6 months (Brandeis, Morris, Nash, et al., 1990).

## Controlling Factors That Impair Healing

Promote successful surgical closure by controlling or correcting factors that may be associated with impaired healing, such as smoking, spasticity, levels of bacterial colonization, incontinence, and urinary tract infection. (Strength of Evidence = C.)

The carbon monoxide and nicotinic acid found in cigarette smoke act as potent vasoconstrictors, compromising arterial inflow to flaps used for operative repair. Smoking also aggravates ischemia by increasing blood viscosity (Read, 1984). In addition, the neutrophils in smokers release excessive amounts of oxidase, which damages tissues and small vessels (Fincham, 1992). The longer the patient can stop smoking before surgery the better; however, it may be 6 weeks before improvements in immune response can be noted (Jones, 1985-86). Cessation for 12 to 24 hours prior to surgery will reduce carbon monoxide and nicotinic acid levels. Nicotine patches should not be used, since their half-life is twice that of smoked tobacco (Fincham, 1992). Although patients would not be denied operative repair just because they choose to continue smoking or cannot stop smoking, they should be counseled about the risk of flap failure (Lewis, 1989).

Spasticity and mass reflex in paraplegic patients may facilitate transfer, but severe spasticity hinders healing after surgery (Herceg and Harding, 1978). Ulcer cleansing may increase spasticity because it acts as a noxious stimulus triggering a spastic reflex (Hall and Young, 1983). After surgery, spasticity can put tension on wound edges and lead to dehiscence. Joint or muscle contracture may require surgical release to decrease wound tension (Haher, Haher, Devlin, et al., 1983).

Levels of bacterial colonization in the wound can be controlled and urinary incontinence can be managed with urinary catheters to decrease the risk of wound infection. Urinary tract infection is a common cause of sepsis. Although many clinicians administer perioperative antibiotics prophylactically (Salzberg, Gray, Petro, et al., 1990), there are no research data to support the efficacy of this practice. See Chapter 5, Managing Bacterial Colonization and Infection, and Chapter 4, Ulcer Care.

## Operative Procedures

Use the most effective and least traumatic method to repair the ulcer defect. Wounds can be closed by direct closure, skin grafting, skin flaps, musculocutaneous flaps, and free flaps. To minimize recurrence, the choice of operative technique is based on the individual patient's needs and overall goals. (Strength of Evidence = C.)

Repair of Stage III and IV ulcers requires tissue that will provide bulk, be resistant to pressure, and withstand normal wear and tear. In planning the reconstruction, the clinician begins by determining the simplest technique that will best restore missing tissue and blood supply without sacrificing function. Operative procedures are listed below in order of increasing complexity. Refer to Operative Repair in the Glossary for additional information.

- Direct closure. Although the simplest method of pressure ulcer repair would be direct closure with sutures, this approach stretches the skin and creates tension that frequently leads to dehiscence, especially when the patient moves (Lewis, 1989). Thus, primary closure with a suture is seldom used except for small, superficial ulcers (Anthony, Huntsman, and Mathes, 1992).

- Skin grafts. Skin grafts are the next simplest method of wound closure and are used to repair shallow pressure ulcers. Skin grafts, however, provide only a skin barrier. When applied to granulating bone, skin grafts quickly erode, precluding healing (Nuseibeh, 1974; Sundell, Pentti, and Langenskiold, 1967).

- Skin flaps. Prior to the 1970's, repair using local skin flaps was the standard surgical treatment for ulcers. Today, they are not usually employed for primary repair but are used instead as alternatives for secondary repair (Sanchez, Eamegdool, and Conway, 1969). Local skin flaps have a random vascular supply, and the tissue used for repair is often a redistribution of inadequately perfused tissue rather than a planned revascularization using specific blood vessels. Although some random flaps have a good blood supply, that supply may not be in the zone of injury.

- Musculocutaneous flaps. Musculocutaneous flaps are usually the best choice for paraplegic patients or when loss of muscle function does not contribute to comorbidity. For ambulatory patients the choice is less clear, since the improved blood supply and reliability of the muscle flap must be balanced against the need to sacrifice functional muscle units (Koshima, Moriguchi, Soeda, et al., 1993; Kroll and Rosenfield, 1988; Vyas, Binns, and Wilson, 1980). Musculocutaneous flaps can help heal osteomyelitis and limit the damage caused by shearing, friction, and pressure (Daniel, Hall, and MacLeod, 1979; Mathes, Feng, and Hunt, 1983; Vasconez, Schneider, and Jurkiewicz, 1977).

- Free flaps. Free flaps are muscle-type flaps in which the vein and artery are disconnected at the donor site and reconnected to the vessels at the recipient site with the aid of a microscope. This is the most complex method of wound closure, and it has not been described in the literature for closure of pressure ulcers.

One recent finding in the literature is on the use of tissue expansion techniques, by which surrounding tissues are stretched and rotated to cover pressure ulcers. Advantages of this adjunctive method appear to be that local tissue can be used for operative repair, the three-dimensional expander temporarily provides equal distribution of pressure, and the tissue can be expanded on an outpatient basis. Long-term results are not yet known (Braddom and Leadbetter, 1989; Esposito, Di Caprio, Ziccardi, et al., 1991; Gray, Salzberg, Petro, et al., 1990; Yuan, 1989).

Before recommending a specific operative technique, the clinician will also consider the site of the ulcer. Site-specific considerations are discussed for sacral, ischial, trochanteric, and more extensive pressure ulcers.

- Sacral ulcers. The gluteus maximus is a large muscle that can be used in its entirety or in portions to repair pressure ulcers over the sacrum. Since its vascular supply is ample, use of one portion of the gluteus maximus does not devascularize other portions of the muscle. Disadvantages to its use are that it may be difficult to identify in quadriplegic patients due to atrophy, flap dissection may be bloody, and the flaps are bulky. The gluteus maximus serves as the primary extender, external rotator, and abductor of the hip; therefore, the whole muscle cannot be used as a flap in ambulatory patients without sacrificing hip function (Fisher, Arnold, Waldorf, et al., 1983; Ger and Levine, 1976; Heywood and Quaba, 1989; Minami, Mills, and Pardoe, 1977; Parkash and Banerjee, 1986; Parry and Mathes, 1982; Scheflan, Nahai, and Boswick, 1981). Several types of secondary flaps can be used for operative repair of sacral ulcers (Bailey, 1971; Hill, Brown, and Jurkiewicz, 1978; Lewis, 1989).

- Ischial ulcers. Ischial ulcers can be repaired by using the inferior gluteus maximus musculocutaneous flap. A disadvantage of this approach is that flap advancement requires lateral division of the gluteus maximus muscle, which is contraindicated in an ambulatory patient. Short-term complications were related to flap viability, and ulcer recurrence was uncommon at the site of repair (Baek, Williams, McElhinney, et al., 1980; Lewis, 1989; Maruyama, Ohnishi, and Takeuchi, 1984; Parkash and Banerjee, 1986; Scheflan, Nahai, and Boswick, 1981). The tensor fascia lata (TFL) can also be used for repair (Abramsohn, Murphy, Pandeya, et al., 1981; Lewis, Cunningham, and Hugo, 1981; McGregor and Buchan, 1980). In patients with a sensory loss below L3-4, the TFL flap can be used to provide sensation. Favorable outcomes reported were sensation in the perianal region and improved bowel control (Cochran, Edstrom, and Dibbell, 1981; Coleman and Jurkiewicz, 1984; Daniel, Terzis, and Cunningham, 1976; Krupp, Kuhn, and Zaech, 1983; Luscher, de Roche, Krupp, et al., 1991; Spear, Kroll, and Little, 1987).

- Trochanteric ulcers. Trochanteric ulcers are difficult to repair surgically for several reasons. Incisions needed for local skin flaps may interfere with the design of future flaps to repair other ulcers. In contrast to most other common pressure ulcer sites, the bony prominence beneath a trochanteric ulcer is mobile rather than stationary, which tends to create large areas of undermining and make the adherence of a skin flap difficult. The TFL flap is the first choice of musculocutaneous flaps to repair trochanteric ulcers. Advantages to using the TFL are that the muscle is near the ulcer site, has a consistent vascular pedicle, can provide sensation, is moved easily, and is an expendable muscle. One disadvantage is that a dog-ear deformity is often created (Daniel and Faibisoff, 1982; Daniel, Hall, and MacLeod, 1979; McGregor and Buchan, 1980; Micali and Romeo, 1982; Muguti, 1990; Paletta, Freedman, and Shehadi, 1989; Siddiqui, Wiedrich, and Lewis, 1993). Other musculocutaneous flaps used for repair include the vastus lateralis muscle flap with skin graft coverage (Bovet, Nassif, Guimberteau, et al., 1982; Minami, Hentz, and Vistnes, 1977), the inferior-based gluteus (Becker, 1979; Parkash and Banerjee, 1986), the sartorius (Maruyama and Hamano, 1978), the rectus femoris (Peters, Cartotto, Morris, et al., 1991), and the vastus lateralis (Tolhurst, 1980).

- Extensive pressure ulcers. Extensive pressure ulcers are defined as those that cannot heal on their own and cannot be closed with a single musculocutaneous flap. Several procedures have been discussed in the literature, including a thigh flap (Lawton and De Pinto, 1987; Royer, Pickrell, Georgiade, et al., 1969; Rubayi, Pompan, and Garland, 1991; Sagi, Meller, Kon, et al., 1987; Yanai, Bandoh, and Tsuzuki, 1991); skin flaps from the lower leg, with preservation of the upper leg (Burkhardt, 1972; Chen, Weng, and Noordhoff, 1986; Holman, 1985); and translumbar amputation (hemicorporectomy) (Aust and Page, 1985; Pearlman, McShane, Jochimsen, et al., 1976; Terz, Schaffner, Goodkin, et al., 1990).

Prophylactic ischiectomy is not recommended because it often results in perineal ulcers and urethral fistulas, which are more threatening problems than ischial ulcers. (Strength of Evidence = C.)

Although ischiectomy had been advocated for the treatment as well as the prevention of ischial ulcers (Arregui, Canon, Murray, et al., 1965), recent studies report perineal ulcer occurrence and the development of urethral fistula after this procedure (Hackler and Zampieri, 1987; Karaca, Binns, and Blumenthal, 1978). The ulcers are caused by pressure diverted to the remaining ischium or anterior pelvis.

## Postoperative Care

Minimize pressure to the operative site by use of an air-fluidized bed, a low-air-loss bed, or a Stryker frame for a minimum of 2 weeks. Assess postoperative viability of the surgical site as clinically indicated. Have the patient slowly increase periods of time sitting or lying on the flap to increase its tolerance to pressure. To determine the degree of tolerance, monitor the flap for pallor, redness, or both that do not resolve after 10 minutes of pressure relief. Ongoing patient education is imperative to reduce the risk of recurrence. (Strength of Evidence = C.)

No studies have focused solely on postoperative care and rehabilitation after pressure ulcer repair; therefore, the information in this section is based on expert opinion. Complications of flap reconstruction have included hematoma, wound separation, flap necrosis, flap dehiscence, infection, and seroma (Vasconez, Schneider, and Jurkiewicz, 1977). To reduce the risk of hematoma and seroma, wound suction devices are left in the wound for about 1 week or until drainage is minimal. Many complications are due to insufficient blood supply to the flap. Use of pressure-relieving beds allows the patient to lie on the flap without interfering with tissue perfusion. The head of an air-fluidized bed should not be elevated above 15 degrees from the horizontal. Although some clinicians prefer to place patients in a prone position, complications of this position include airway difficulties (especially in quadriplegic patients), ulnar nerve compression (Nath and Taylor, 1978), confusion, and boredom. When the patient's position is changed, the flap should not be subjected to friction or shear.

Following sacral ulcer repair, fecal contamination of the wound should be avoided. This can be accomplished by using constipating medications and a low-fiber diet (Black and Black, 1987; Rubayi, Cousins, and Valentine, 1990).

Rehabilitation of the patient with a flap includes progressively longer periods of sitting, with flap viability checked after each sitting period. Flap viability may be compromised if pallor, redness, or both at the operative site do not decrease after 10 minutes of pressure relief (Bih and Lu, 1989). Patients are taught to shift their body weight once they are bearing weight on the flap and to inspect the skin daily using a mirror. See Chapter 3, Managing Tissue Loads, for more specific recommendations on techniques for positioning and pressure reduction when the patient is sitting or in bed.

Assess for recurrence of pressure ulcers as an ongoing component of care. Caregivers should provide education and encourage adherence to measures for pressure reduction, daily skin examination, and intermittent relief techniques. (Strength of Evidence = A.)

Recurrence rates for pressure ulcers following operative repair range from 13 percent (Mandrekas and Mastorakos, 1992) to 56 percent (Relander and Palmer, 1988). Carelessness and noncompliance are important risk factors for recurrence (Disa, Carlton, and Goldberg, 1992; Morgan, 1976).

Disa, Carlton, and Goldberg (1992) compared ulcer recurrence after surgery in various groups of patients. The incidence of new ulcers in the traumatic, paraplegic group was 79 percent, compared with 29 percent in the nontraumatic, nonparaplegic group (which consisted mainly of elderly nursing home residents), and 0 percent in the nontraumatic paraplegic group. Adequate social support was associated with lack of recurrence, and substance abuse was related to recurrence.

Recurrence rates may be reduced with the use of sensate flaps. More important, however, is the development of programs in ulcer prevention, with emphasis on patient education and adherence. The long-term preventive value of musculocutaneous flap coverage of pressure ulcers must be continually reevaluated in a large series of patients.