# Managing Tissue Loads

The goal of the following recommendations is to create an environment that enhances soft tissue viability and promotes healing of the pressure ulcer(s). The term "tissue load" refers to the distribution of pressure, friction, and shear on the tissue. The interventions are designed to decrease the magnitude of tissue loads and to provide levels of moisture and temperature that support tissue health and growth. The algorithm in Figure 3 will help guide clinical decisions on the management of tissue loads.

## While in Bed

Positioning techniques and support surfaces for patients in bed are important factors in the management of tissue loads.

### Positioning Techniques

Avoid positioning patients on a pressure ulcer. (Strength of Evidence = C.)

Because pressure that is of sufficient intensity and duration to cause soft tissue ischemia and necrosis contributes to the development of pressure ulcers (Kosiak, 1959), it is reasonable to assume that pressure on an ulcer can delay healing.

Use positioning devices to raise a pressure ulcer off the support surface. If the patient is no longer at risk for developing pressure ulcers, these devices may reduce the need for pressure-reducing overlays, mattresses, and beds. Avoid using donut-type devices. (Strength of Evidence = C.)

If a pressure ulcer involves a circumscribed area such as the heel or the back of the head and if the patient is able to reposition the rest of his or her body independently, then using positioning devices to raise the involved area off the support surface may be adequate for healing.

Although ring cushions (donuts) are known to cause venous congestion and edema, few studies have documented their deleterious effects. Crewe (1987), in a study of at-risk patients, found that ring cushions are more likely to cause pressure ulcers than to prevent them.

Establish a written repositioning schedule. (Strength of Evidence = C.)

The schedule for repositioning the patient should be designed to protect uninvolved areas. It should be based on the degree to which the individual is at risk for developing additional pressure ulcers and on the response of the tissue to pressure. Thus, the higher the risk for additional pressure ulcers and the longer the duration of reactive hyperemia, the more frequently the patient should be repositioned.

When the number of pressure ulcers, the patient's condition, or the overall treatment goals make it impossible to avoid positioning a patient on a pressure ulcer, the clinician who is designing the repositioning schedule should keep in mind the need to decrease the duration of pressure on these areas.

Written repositioning schedules should be developed even when patients are using a pressure-reducing support surface. There are numerous reports that patients develop pressure ulcers while using pressure-reducing support surfaces, regardless of the type of surface (Allman, Walker, Hart, et al., 1987; Conine, Daechsel, and Lau, 1990; Jackson, Chagares, Nee, et al., 1988; Parish and Witkowski, 1980; St. St.Clair, 1992). These surfaces serve only as adjuncts to strategies for positioning and careful monitoring of at-risk patients.

Assess all patients with existing pressure ulcers to determine their risk for developing additional pressure ulcers. For those individuals who remain at risk, institute the following measures recommended in Pressure Ulcers in Adults: Prediction and Prevention. Clinical Practice Guideline, No. 3:

- Avoid positioning immobile individuals directly on their trochanters and use devices such as pillows and foam wedges that totally relieve pressure on the heels, most commonly by raising the heels off the bed. (Strength of Evidence = C.)
  - Redistributing pressure under the heels and over the trochanters is difficult because of the small surface area. Investigators who have measured interface pressure between these areas and support surfaces consistently report high pressures.
- Use positioning devices such as pillows or foam to prevent direct contact between bony prominences (such as knees or ankles). (Strength of Evidence = C.)
  - This recommendation is based on the usual practice and standards developed by professional organizations.
- Maintain the head of the bed at the lowest degree of elevation consistent with medical conditions and other restrictions. Limit the amount of time the head of the bed is elevated. (Strength of Evidence = C.)
  - Shearing forces are produced when adjacent surfaces slide across one another. Shear is exerted on the body when the head of the bed is elevated. In this position, the skin and superficial fascia remain fixed against the bed linens while the deep fascia and skeleton slide down toward the foot of the bed. Shear forces are also generated when individuals sitting in a chair slide down in the chair. As a result of shear, blood vessels in the sacral area are likely to become twisted and distorted, and tissue may become ischemic and necrotic (Reichel, 1958). It has been suggested that shear forces contribute to the undermining seen in some sacral ulcers. Standards of professional organizations and clinical articles advocate the use of positioning techniques and devices to help individuals maintain their position in bed or chair.

### Support Surfaces

When one is selecting a support surface for a patient, the primary concern should be the therapeutic benefit associated with the product. A variety of support surfaces has been shown to provide an environment in which pressure ulcers improve, but there is no compelling evidence that one support surface consistently performs better than all others, under all circumstances (Allman, Walker, Hart, et al., 1987; Conine, Daechsel, and Lau, 1990; Ferrell, Osterweil, and Christenson, 1993; ; Munro, Brown, and Heitman, 1989; Strauss, Gong, Gary, et al., 1991; Warner, 1992; Wiersema and Lueckenotte, 1992). Therefore, the caregiver should consider a variety of factors when selecting a support surface, including the clinical condition of the patient, the characteristics of the care setting, and the characteristics of the support surface.

Table 1 categorizes the various classes of support surfaces according to their performance in counteracting the different forces that contribute to the development of pressure ulcers. After determining which of these forces might be increasing an individual's risk for pressure ulcers, the caregiver may find this table useful in selecting a support surface for a particular patient. In addition to considering the features listed in Table 1, caregivers also need to consider other performance factors, such as ease of use, requirements for maintenance, cost, and patient preference (Conine, Choi, and Lim, 1989); (Doughty, Fairchild, and Stogis, 1990).

Table 1. Selected characteristics for classes of support surfaces

| Support Devices
Performance Characteristics | Air-fluidized | Low-air loss | Alternating Air | Static Flotation (air or water) | Foam | Standard Mattress
Increased support area | Yes | Yes | Yes | Yes | Yes | No
Low moisture retention | Yes | Yes | No | No | No | No
Reduced heat accumulation | Yes | Yes | No | No | No | No
Shear reduction | Yes | ? | Yes | Yes | No | No
Pressure reduction | Yes | Yes | Yes | Yes | Yes | No
Dynamic | Yes | Yes | Yes | No | No | No
Cost per day | High | High | Moderate | Low | Low | Low

It is important to remember that support surfaces are only one component of a comprehensive treatment plan. If an ulcer does not heal, the entire plan should be reevaluated before the support surface is changed.

Assess all patients with existing pressure ulcers to determine their risk for developing additional pressure ulcers. If the patient remains at risk, use a pressure-reducing surface. (Strength of Evidence = C.)

Patients with existing pressure ulcers may still be at risk for additional pressure ulcers and may therefore need the protection provided by a pressure-reducing surface.

Use a static support surface if a patient can assume a variety of positions without bearing weight on a pressure ulcer and without "bottoming out." (Strength of Evidence = B.)

Although pressure ulcers have been shown to heal when a static support surface is used (Conine, Daechsel, and Lau, 1990; Ferrell, Osterweil, and Christenson, 1993; Warner, 1992; Wiersema and Lueckenotte, 1992), there is no evidence that one type of static support surface is more effective than another. No statistically significant difference in pressure ulcer outcomes has been demonstrated among the available static support surfaces, and thus choice of the static support surface is left to the caregiver. When selecting a static support surface made of foam, caregivers should consider the following characteristics of the foam: stiffness, density, and thickness. Indentation load deflection (ILD) is a measure of stiffness. Typical values for foam mattress overlays would be a 25-percent ILD of 30 pounds, a density of 1.3 pounds per cubic foot, and a thickness of 3 to 4 inches (Kemp and Krouskop, 1994).

The phenomenon of "bottoming out" can be a problem when a mattress overlay is used. The caregiver can determine whether the patient has bottomed out by placing an outstretched hand (palm up) under the overlay below the pressure ulcer or below the part of the body at risk for a pressure ulcer. If the caregiver feels less than an inch of support material, the patient has bottomed out. Bottoming out should be checked at various anatomical sites and while the patient assumes various body positions. For example, when the patient is supine, check for bottoming out at the sacrum and heels. When the patient is side lying, check at the trochanter. When the patient is sitting, check at the ischial tuberosities.

Use a dynamic support surface if the patient cannot assume a variety of positions without bearing weight on a pressure ulcer, if the patient fully compresses the static support surface, or if the pressure ulcer does not show evidence of healing. (Strength of Evidence = B.)

Although some patients with pressure ulcers improve when cared for on a static support surface, there is evidence that others have a better pressure ulcer outcome when cared for on a dynamic support surface (Ferrell, Osterweil, and Christenson, 1993). The dynamic support surface should be dependable and capable of lifting the individual and preventing bottoming out.

If a patient has large Stage III or Stage IV pressure ulcers on multiple turning surfaces, a low-air-loss bed or an air-fluidized bed may be indicated. (Strength of Evidence = C.)

There is some evidence that patients in the acute care setting who have large pressure ulcers may benefit from the use of an air-fluidized bed (Allman, Walker, Hart, et al., 1987). Several groups have developed criteria for selecting pressure-reducing support surfaces and have targeted patients with Stage III and Stage IV pressure ulcers for treatment on air-fluidized beds (National Center for Cost Containment, 1992; Nimit, 1989; University Hospital Consortium, 1990). Although air-fluidized beds may benefit some patients, these beds are very heavy, and not all structures can accommodate them. Furthermore, transferring patients in and out of air-fluidized beds is difficult (Allman, Walker, Hart, et al., 1987; Smoot, 1986), and adverse side effects (e.g., corneal abrasion from loose beads) have been reported (Smoot, 1986). These drawbacks should be considered before one chooses this type of support surface. Additional studies of air-fluidized bed therapy are needed, particularly in long-term care settings.

Four randomized controlled trials of low-air-loss beds involving a total of 259 subjects with pressure ulcers were reviewed (Ferrell, Osterweil, and Christenson, 1993; Mulder and Seeley, 1991; Warner, 1992; Wiersema and Lueckenotte, 1992). The healing and improvement rates for low-air-loss therapy ranged from 64 to 80 percent in these four studies, and the control therapies showed rates ranging from 47 to 68 percent. One trial involving 84 nursing home residents showed that healing occurred 2.5 times faster among subjects on low-air-loss beds than among those on foam mattresses -- a statistically significant difference (Ferrell, Osterweil, and Christenson, 1993). The other three trials were performed in acute care hospitals, and differences in wound healing outcomes for patients on low-air-loss beds versus control treatments did not reach statistical significance in these studies. This may be due to the real absence of clinically important differences in outcome or to characteristics of the research design and implementation (such as inadequate sample sizes or the shorter length of followup possible in acute care settings). Determining the effectiveness of low-air-loss beds definitively will require larger studies with longer followup periods, particularly in the acute care hospital setting.

No studies have compared the effectiveness of low-air-loss beds and air-fluidized beds. Unlike air-fluidized beds, low-air-loss beds can be raised and lowered, and the heads of these beds can be elevated. In addition, transferring patients in or out of bed is easier with low-air-loss than with air-fluidized beds. Except in settings with special contract rental fees, air-fluidized beds are more expensive than low-air-loss beds. For these reasons, clinicians generally prefer low-air-loss beds for individuals who need a specialized support surface. A randomized controlled trial will be required to compare low-air-loss bed and air-fluidized bed therapy.

When excess moisture on intact skin is a potential source of maceration and skin breakdown, a support surface that provides airflow can be important in drying the skin and preventing additional pressure ulcers. (Strength of Evidence = C.)

Moist skin is more likely to abrade and blister (Leyden, 1984; Leyden, Katz, Stewart, et al., 1977; Zimmerer, Lawson, and Calvert, 1986). When using support surfaces that increase airflow across the patient's skin (e.g., air-fluidized beds and low-air-loss beds), the caregiver should follow manufacturers' instructions for using linens and underpads. When patients are lying on this type of support surface, they should not wear adult incontinence briefs, because these briefs obstruct airflow to the skin.

## While Sitting

Positioning techniques and support surfaces for patients who are sitting are important factors in the management of tissue loads.

### Positioning Techniques

A patient who has a pressure ulcer on a sitting surface should avoid sitting. If pressure on the ulcer can be relieved, limited sitting may be allowed. (Strength of Evidence = C.)

Interface pressure between the ischial tuberosities and seating surfaces is high and must be relieved frequently to prevent soft tissue damage (Drummond, Narechania, Rosenthal, et al., 1982). Individuals whose sensation is impaired cannot perceive ischemic pain and thus lack a natural defense against pressure ulcers. Those whose mobility is impaired are unable to reposition themselves independently. Thus, both groups depend on outside resources to either relieve pressure for them or remind them to relieve pressure (Merbitz, King, Bleiberg, et al., 1985). As a result, they are prone to numerous episodes of prolonged, unrelieved pressure and should avoid sitting unless pressure over the pressure ulcer can be totally relieved.

Consider postural alignment, distribution of weight, balance, stability, and pressure relief when positioning sitting individuals. (Strength of Evidence = C.)

So that individuals with pressure ulcers can participate in activities of daily living, leisure activities, and personal interactions, a seat must provide more than pressure relief. If the seating surface interferes with these pursuits, individuals are less likely to use the device and thus lack the protection necessary for maintaining healthy skin. Seating considerations to promote maximum personal autonomy and a healthy lifestyle include proper postural alignment and distribution of weight, balance and stability, and pressure relief (Hobson, 1992; Park, 1992). Proper postural alignment reduces the risk for deformities that could compromise respiratory function as well as self-care activities. Proper distribution of weight over the seating surface influences the person's ability to transfer from the seat, defines the magnitude and location of maximum pressure, and allows the load to be transferred to areas that can better tolerate the mechanical loading (Bush, 1969; Drummond, Breed, and Narechania, 1985). Balance and stability directly influence mobility, energy expenditure, and function performance.

Reposition the sitting individual so the points under pressure are shifted at least every hour. If this schedule cannot be kept or is inconsistent with overall treatment goals, return the patient to bed. Individuals who are able should be taught to shift their weight every 15 minutes. (Strength of Evidence = C.)

Research on the etiology of pressure ulcers has indicated that prolonged, uninterrupted mechanical loading of the tissue leads to its breakdown (Kosiak, 1959; Reddy and Cochran, 1979). According to the pressure-time curve developed by Brand (1976), the interface pressure produced during sitting should be relieved at least every hour and preferably at shorter intervals. Clinical practitioners who work with spinal cord-injured patients report that weight shifts are often effective for preventing pressure ulcer formation (Krouskop, Noble, Garber, et al., 1983).

### Support Surfaces

Select a cushion based on the specific needs of the individual who requires pressure reduction in a sitting position. Avoid donut-type devices. (Strength of Evidence = C.)

On the basis of the results of animal experiments (Lindan, 1961; Reddy and Cochran, 1979), reducing mechanical loading on the tissue through the use of pressure-reducing devices can diminish the risk for pressure ulcer formation (DeLateur, Berni, Hangladarom, et al., 1976; Ferguson-Pell, Cochran, Cardi, et al., 1986; Garber, Krouskop, and Carter, 1978). For optimal effectiveness, the device must be individually prescribed based on the individual's contour and anatomy and must not interfere with other aspects of mobility and personal autonomy. Pressure-reducing devices allow the individual increased latitude when pressure relief must be provided (for example, when push-ups must be done) and in the timing of nursing care schedules.

Ring cushions (donuts) are known to cause venous congestion and edema, although few studies have been carried out to document their deleterious effects. In a study of at-risk patients, Crewe (1987) found that ring cushions are more likely to cause pressure ulcers than to prevent them.

Develop a written plan for the use of positioning devices. (Strength of Evidence = C.)

This recommendation is consistent with usual clinical practice. The use of positioning devices for wheelchair users has been endorsed by several authors (Hamilton, Quek, Lew, et al., 1989; King and French, 1990).