# Assessment

Assessment is the starting point in preparing to treat or manage an individual with a pressure ulcer. Assessment involves the entire person, not just the ulcer, and is the basis for planning treatment and evaluating its effects. Adequate assessment is also essential for communication among caregivers. This chapter provides recommendations for assessing both the pressure ulcer and the individual. Assessment of the individual addresses physical health, common complications, nutritional status, pain level, and psychosocial health.

## Assessing the Pressure Ulcer

Assess the pressure ulcer(s) initially for location, stage (NPUAP, 1989), size, sinus tracts, undermining, tunneling, exudate, necrotic tissue, and the presence or absence of granulation tissue and epithelialization. (See Attachment A for a sample pressure ulcer assessment guide.) (Strength of Evidence = C.)

Pressure ulcers should be uniformly described to facilitate communication among staff and to ensure adequate monitoring of the progress toward healing. The system developed by the National Pressure Ulcer Advisory Panel (NPUAP, 1989) is a synthesis of the most commonly used staging methods. Necrotic tissue must be removed before the stage of the ulcer can be determined. To monitor progress or deterioration of the lesion, the examiner must accurately measure the length, width, and depth of the ulcer and describe sinus tracts, tunneling, undermining, necrotic tissue, exudate, and the presence or absence of granulation tissue and epithelialization (Yarkony, Kirk, Carlson, et al., 1990). Color photographs, taken on initial assessment and reevaluation, are very helpful in monitoring ulcer healing.

Reassess pressure ulcers at least weekly (as shown in Attachment A). If the condition of the patient or of the wound deteriorates, reevaluate the treatment plan as soon as any evidence of deterioration is noted. (Strength of Evidence = C.)

To determine the adequacy of the treatment plan, it is essential to monitor pressure ulcers at consistent intervals. Assessment and documentation should be carried out at least weekly, unless there is evidence of deterioration, in which case both the pressure ulcer and the patient's overall management must be reassessed immediately. In the home setting, this may require the assistance of the patient and family, because weekly assessment by health care providers is not always feasible.

Indicators of a deteriorating pressure ulcer include increases in exudate and wound edema, loss of granulation tissue, and a purulent discharge. The onset of impaired mental status, fever, hypotension, and tachycardia may indicate sudden deterioration of the patient's physical status.

A comprehensive literature review failed to identify one tool for reassessment and monitoring that could be recommended. The suggested assessment guide is based on the work of Bates-Jensen (1990) and numerous other investigators; with further research, the Bates-Jensen scale may prove useful for monitoring and reassessment. However, to date, no one tool for reassessment and monitoring can be recommended.

A clean pressure ulcer should show evidence of some healing within 2 to 4 weeks. If no progress can be demonstrated, reevaluate the adequacy of the overall treatment plan as well as adherence to this plan, making modifications as necessary. (Strength of Evidence = C.)

A pressure ulcer with adequate innervation and vascular supply should show evidence of healing within 2 to 4 weeks (Robson, Phillips, Thomason, et al., 1992b; van Rijswijk, 1993). Suboptimal healing may be attributed to inadequacies of the treatment plan or failure to adhere to the treatment plan (e.g., failure to alleviate the pressure, to apply proper dressings, or to correct nutritional deficiencies). These contributing factors can be influenced by psychosocial or economic variables. Although healing is always the preferred goal, maintenance of comfort may be an appropriate goal for a terminally ill patient.

## Assessing the Individual With a Pressure Ulcer

### History and Physical Examination

Perform a complete history and physical examination, because a pressure ulcer should be assessed in the context of the patient's overall physical and psychosocial health. (Strength of Evidence = C.)

Efforts to ensure good health require a thorough understanding of the individual patient's overall physical and mental status regardless of the specific illness being treated. In the case of pressure ulcers, the individual's capacity to heal may be limited by comorbid illnesses such as peripheral vascular disease, diabetes mellitus, immune deficiencies, collagen vascular diseases, malignancies, psychosis, and depression (Lazarus, Cooper, Knighton, et al., 1992).

### Assessing Complications

Clinicians should be alert to the potential complications associated with pressure ulcers. (Strength of Evidence = C.)

The following complications are associated with pressure ulcers:

- Amyloidosis (Melcher, Longe, and Gelbart, 1988).
- Endocarditis (Schwartz and Pervez, 1971).
- Heterotopic bone formation (Reuler and Cooney, 1981).
- Maggot infestation (Roche, Cross, Burgess, et al., 1990).
- Meningitis (Soriano, Aguado, Tornero, et al., 1986).
- Perineal-urethral fistula (Hackler and Zampieri, 1987).
- Pseudoaneurysm (Wang, Lineaweaver, Scott, et al., 1987).
- Septic arthritis (Klein, Moore, Capen, et al., 1988).
- Sinus tract or abscess (Putnam, Calenoff, Betts, et al., 1978).
- Squamous cell carcinoma in the ulcer (Berkwits, Yarkony, and Lewis, 1986).
- Systemic complications of topical treatment -- e.g., iodine toxicity (Shetty and Duthie, 1990) and hearing loss after topical neomycin and systemic gentamicin (Johnson, 1988).

Three other complications -- osteomyelitis, bacteremia, and advancing cellulitis -- are discussed in Chapter 5, Managing Bacterial Colonization and Infection.

The clinician who is treating a patient with a pressure ulcer must be aware of the numerous possible complications of pressure ulcers that have been reported in the literature. Some complications are infectious, such as abscess, sinus tract, meningitis, and endocarditis, and others are noninfectious. Even a relatively small opening in the skin can connect with an extensive cavity or with a deeply penetrating sinus tract. Computerized tomography (CT) scanning was reported to be effective in detecting deep abscesses associated with pressure ulcers (Firooznia, Rafii, Golimbu, Sokolow, 1983A). (Firooznia, Rafii, Golimbu, Sokolow, 1983B). Sinography was reported to be useful for defining the extent of sinus tracts underlying pressure ulcers (Hooker, Sibley, Nemchausky, et al., 1988; Putnam, Calenoff, Betts, et al., 1978). The clinician must also be aware that some treatments of pressure ulcers may lead to other complications. For example, topical treatment with iodine-containing agents may unmask subclinical hyperthyroidism (Shetty and Duthie, 1990) or result in iodine toxicity (Aronoff, Friedman, Doedens, et al., 1980). Topical aminoglycoside treatment has been associated with hearing loss (Johnson, 1988).

### Nutritional Assessment and Management

Because many studies have linked pressure ulcers with malnutrition, screening for nutritional deficiencies is an important part of the initial assessment. The goal of nutritional assessment and management is to ensure that the diet of the individual with a pressure ulcer contains nutrients adequate to support healing. The following recommendations and the algorithm depicted in Figure 2 are designed to guide the clinician in meeting this goal.

Ensure adequate dietary intake to prevent malnutrition to the extent that this is compatible with the individual's wishes. (Strength of Evidence = B.)

Multiple studies indicate that malnutrition is a risk factor for pressure ulcer formation. Furthermore, the stage of the wound is correlated with the severity of nutritional deficits, particularly low protein intake or a below-normal serum albumin (Allman, Laprade, Noel, et al., 1986; Bergstrom and Braden, 1992; Berlowitz and Wilking, 1989; Breslow, Hallfrisch, and Goldberg, 1991; Ek, Unosson, and Bjurulf, 1989; Hanan and Scheele, 1991; Holmes, Macchiano, Jhangiani, et al., 1987; Pinchcofsky-Devin and Kaminski, 1986). Prevention of malnutrition will reduce an individual's risk for ulcer formation.

Perform an abbreviated nutritional assessment, as defined by the Nutrition Screening Initiative, at least every 3 months for individuals at risk for malnutrition. These include individuals who are unable to take food by mouth or who experience an involuntary change in weight. (Strength of Evidence = C.)

In patients at risk for malnutrition, an involuntary increase or decrease in weight of 5 percent is predictive of a drop in serum albumin (Nutrition Screening Manual for Professionals Caring for Older Americans: Nutrition Screening Initiative, 1991). Because the state of hydration affects weight and albumin concentration, it should also be part of a nutritional screening assessment. (Attachment B is a sample assessment guide.) Clinically significant malnutrition is diagnosed if (1) serum albumin is less than 3.5 mg/dL, (2) total lymphocyte count is less than 1,800/mm[sup]3, or (3) body weight has decreased more than 15 percent. Oral and cutaneous signs of vitamin or mineral deficiencies should also be considered during the nutritional assessment. (Attachment C lists these signs.)

Encourage dietary intake or supplementation if an individual with a pressure ulcer is malnourished. If dietary intake continues to be inadequate, impractical, or impossible, nutritional support (usually tube feeding) should be used to place the patient into positive nitrogen balance (approximately 30 to 35 calories/kg/day and 1.25 to 1.50 grams of protein/kg/day) according to the goals of care. (Strength of Evidence = C.)

A review of the literature suggests that a pressure ulcer can be a grave indicator of malnutrition. Breslow, Hallfrisch, Guy, et al. (1993) found that high-protein diets with increased caloric contents may enhance pressure ulcer healing in malnourished nursing home patients. When the nutritional assessment confirms that the individual is malnourished, the first intervention consists of assisted oral feeding and oral supplements. A second assessment should be done within 3 working days to determine whether intake goals have been achieved. If intake is still inadequate, tube feeding should be initiated to achieve a positive nitrogen balance.

Tests to assess nitrogen balance may not be practical in all settings. For most patients, however, positive nitrogen balance is usually accomplished when intake reaches 30 to 35 calories/kg/day and 1.25 to 1.50 grams of protein/kg/day (Chernoff, Milton, and Lipschitz, 1990; Kaminski, 1976), although as much as 2.00 grams of protein/kg/day may be needed Mulholland, Tui, Wright, et al., 1943). Several reports showed that the presence of a feeding tube in a patient with a pressure ulcer does not necessarily mean that he or she is receiving adequate support (Nutrition Screening Manual for Professionals Caring for Older Americans: Nutrition Screening Initiative, 1991). Repeat nutritional assessments, including measurements of serial protein markers such as serum albumin, should be used to evaluate nutritional support. Monitoring for safety and tolerance, including the possibility of loose bowel movements related to tube feedings, should also be ongoing. (Attachment D outlines the steps in the practical management of loose bowel movements in tube-fed patients.)

Give vitamin and mineral supplements if deficiencies are confirmed or suspected. (Strength of Evidence = C.)

Vitamin and mineral deficiencies have been demonstrated in the majority of patients in nursing home studies (Bergstrom and Braden, 1992; Pinchcofsky-Devin and Kaminski, 1986). There is some evidence that vitamin C and zinc supplementation may aid healing in the presence of deficiencies (Burr, 1973; Taylor, Rimmer, Day, et al., 1974). (Attachment C identifies possible oral and cutaneous signs of vitamin deficiencies.) A daily high-potency vitamin and mineral supplement is recommended for all patients suspected of having vitamin deficiencies. When specific deficiencies are diagnosed, individual supplements of up to 10 times the Recommended Daily Allowance (RDA) for water-soluble vitamins may have to be added to the patient's daily dietary intake (Chen and Fan-Chiang, 1981; Cruz Santiago, Kaminski, and Palencia Salinas, 1981; Williams, Lines, and McKay, 1988).

### Pain Assessment and Management

The goal of pain management in the pressure ulcer patient is to eliminate the cause of the pain, to provide analgesia, or both. Additional information regarding pain assessment and management is provided in Acute Pain Management: Operative or Medical Procedures and Trauma. Clinical Practice Guideline, No. 1.

Assess all patients for pain related to the pressure ulcer or its treatment. (Strength of Evidence = C.)

Even though the literature on the subject of pain is considerable, including assessment and management (both in general and related to particular sites and causes), there is only cursory mention of pressure ulcer pain. Clinicians report anecdotally that they observe patients reacting to pressure ulcer-related pain during turning, dressing changes, and debridement (Black and Black, 1987; Tudhope, 1984); however, considerable research is needed in this area. Meanwhile, the clinician should recognize that such pain may exist and should assess for its presence. Assessment tools can be found in the acute pain management guideline. Caregivers should not assume because a patient cannot express or respond to pain that it does not exist. Because pain may be evoked or may be especially acute during dressing changes and debridement, the caregiver should try to prevent such discomfort or take steps to relieve it (Acute Pain Management Guideline Panel, 1992).

Manage pain by eliminating or controlling the source of pain (e.g., covering wounds, adjusting support surfaces, repositioning). Provide analgesia as needed and appropriate. (Strength of Evidence = C.)

Management of pressure ulcer-associated pain may require several simultaneous interventions. For example, a combination of repositioning, covering a wound, and systemic analgesia may be needed to relieve pain. The effectiveness of the intervention should be evaluated, with adjustments based on the patient's verbal and physiological responses (Acute Pain Management Guideline Panel, 1992). Research needs to be conducted to determine the most effective pain management techniques for pressure ulcer pain.

### Psychosocial Assessment and Management

The goal of a psychosocial assessment is to gather the information necessary to formulate a plan of care consistent with individual and family preferences, goals, and abilities. The goal of psychosocial management is to create an environment conducive to patient adherence to the pressure ulcer treatment plan.

All individuals being treated for pressure ulcers should undergo a psychosocial assessment to determine their ability and motivation to comprehend and adhere to the treatment program. The assessment should include but not be limited to the following:

- Mental status, learning ability, depression.
- Social support.
- Polypharmacy or overmedication.
- Alcohol and/or drug abuse.
- Goals, values, and lifestyle.
- Sexuality.
- Culture and ethnicity.
- Stressors.

Periodic reassessment is recommended. (Strength of Evidence = C).

This recommendation is based primarily on expert clinical opinion, because little direct research evidence links psychosocial variables with the management of pressure ulcers. There is evidence that mean depression scores are higher among spinal cord-injured individuals who are at high risk for pressure ulcers (Fuhrer, Rintala, Hart, et al., 1993). Knowledge, compliance with treatment, and quality of participation in group psychosocial intervention sessions are reported to be associated with healing (LaMantia, Hirschwald, Goodman, et al., 1987). Other psychosocial variables shown to be related to the incidence of pressure ulcers may also be associated with healing. For example, satisfaction with life activities and responsibility for skin care were associated with a lower incidence of pressure ulcers (Anderson and Andberg, 1979), and alcoholism was associated with a higher incidence of pressure ulcers (Vidal and Sarrias, 1991). Psychosocial counseling and education regarding self-care were found to be associated with positive outcomes related to pressure ulcers (Krouskop, Noble, Garber, et al., 1983).

Assess resources (e.g., availability and skill of caregivers, finances, equipment) of individuals being treated for pressure ulcers in the home. (Strength of Evidence = C.)

This recommendation is based on expert clinical opinion. A successful treatment program in the home requires adequate caregiver and equipment resources (Hentz, 1979). Caregivers need to be evaluated for their ability to comprehend and implement the treatment requirements. Caregivers should also be evaluated for their level of strength and endurance. Economic factors should be considered, because they may limit the supply and avail- ability of equipment as well as opportunities to relieve caregivers.

Set treatment goals consistent with the values and lifestyle of the individual, family, and caregiver. (Strength of Evidence = C.)

This recommendation is based on expert clinical opinion. The clinician should collaborate with the individual and the family in setting treatment goals and should provide opportunities to make adjustments in the treatment plan based on specific needs and preferences of the individual, family, and other caregivers.

Arrange interventions to meet identified psychosocial needs and goals. Followup should be planned in cooperation with the individual and caregiver. (Strength of Evidence = C.)

This recommendation is based on expert clinical opinion. If any of the variables in the psychosocial assessment is found to influence adherence with treatment, efforts should be made -- with input from the individual and family members -- to alter the situation to enhance effectiveness of treatment. Psychological counseling and education reduced the recurrence of pressure ulcers among patients with spinal cord injuries who were living in the community (Krouskop, Noble, Garber, et al., 1983).