# Overview

## Introduction

On December 19, 1989, the Omnibus Budget Reconciliation Act (Public Act 101-239) added a new Title IX to the Public Health Service Act establishing the Agency for Health Care Policy and Research (AHCPR). AHCPR's goal is to enhance the quality, appropriateness, and effectiveness of health care services. Section 911 of the Act establishes within AHCPR the Office of the Forum for Quality and Effectiveness in Health Care (the Forum). Section 912 directs the Forum to facilitate the development and periodic review and updating of:

Clinically relevant guidelines that may be used by physicians, educators, and health care practitioners to assist in determining how diseases, disorders, and other health care conditions can most effectively and appropriately be prevented, diagnosed, treated, and managed clinically.

The topic of prediction, prevention, and treatment of pressure ulcers was selected as one of seven topics for initial guideline development based on this mandate, legislative criteria for guideline topics, input from the Nursing Panel for Guideline Development, and the published report of a Consensus Development Conference on pressure ulcers by the National Pressure Ulcer Advisory Panel (NPUAP, 1989). Realizing that prevention of this debilitating condition is less costly than treatment, the panel initially developed Pressure Ulcers in Adults: Prediction and Prevention. Clinical Practice Guideline, No. 3. This initial guideline recommended strategies for identifying at-risk individuals, implementing preventive measures, and treating early (Stage I) pressure ulcers. Unfortunately, not all pressure ulcers can be prevented and those that do develop may become chronic. The current guideline provides a comprehensive plan for treating Stage II, III, and IV pressure ulcers. Because individuals with pressure ulcers are at risk for developing additional ulcers, caregivers are encouraged to consider the recommendations offered in the prevention guideline.

The purpose of Treatment of Pressure Ulcers. Clinical Practice Guideline, No. 15, is to offer recommendations for the treatment of pressure ulcers. It is intended for clinicians who examine and treat persons with pressure ulcers. Clinicians using this guideline may include family physicians, internists, geriatricians, physiatrists, nurses and nurse practitioners, enterostomal therapists, infection control officers, physical and occupational therapists, psychological support staff, dietitians, and other health care providers working in acute care, long-term care, rehabilitative, geriatric, and home settings. The recommendations may also be useful to health care administrators, policy analysts, regulatory agencies, and third-party payers.

Patients and family caregivers are integral to the management team in all settings and during all phases of treatment. They should be apprised of the benefits and harms of available treatment options. Pressure ulcer treatment should be consistent with patient goals, and patient preferences should be respected. The panel believes that these recommendations are applicable to patients seeking palliative as well as restorative care.

These recommendations are not intended to address any other types of wounds, acute or chronic (e.g., diabetic foot ulcers), or those due to vascular disease (venous stasis or arterial insufficiency), neuropathy, neoplasm, primary skin disease, or thermal or chemical injury. Although these recommendations are based on research involving adults, they may, at the clinician's discretion, be applied to children; however, treatment of neonates may differ from that of children and adults.

The recommended treatment program incorporates (1) assessment of the patient and the pressure ulcer, (2) tissue load management, (3) ulcer care, (4) managing bacterial colonization and infection, (5) operative repair, and (6) education and quality improvement. Although panel members considered a broad range of treatment options, they ultimately recommended only those interventions supported by scientific evidence, expert clinical opinion, or both.

## Definitions

A pressure ulcer is any lesion caused by unrelieved pressure resulting in damage of underlying tissue. Pressure ulcers are usually located over bony prominences and are graded or staged to classify the degree of tissue damage observed. Such staging is used as a tool for communication and assessment. The recommendations regarding staging put forth by this panel are consistent with those of the National Pressure Ulcer Advisory Panel Consensus Development Conference (NPUAP, 1989), as derived from previous staging systems proposed by Shea (1975) and the Wound Ostomy and Continence Nurses Society (WOCN) (International Association of Enterostomal Therapy, 1988). Numerical identification of stages does not necessarily imply a progression in ulcer severity. For example, a Stage I ulcer may have very little tissue damage or it may have necrotic underlying tissue, because muscle tissue is more sensitive than skin to pressure-induced ischemia. Pressure ulcers are staged as follows:

- Stage I: Nonblanchable erythema of intact skin, the heralding lesion of skin ulceration. In individuals with darker skin, discoloration of the skin, warmth, edema, induration, or hardness may also be indicators.
- Stage II: Partial thickness skin loss involving epidermis, dermis, or both. The ulcer is superficial and presents clinically as an abrasion, blister, or shallow crater.
- Stage III: Full thickness skin loss involving damage to or necrosis of subcutaneous tissue that may extend down to, but not through, underlying fascia. The ulcer presents clinically as a deep crater with or without undermining of adjacent tissue.
- Stage IV: Full thickness skin loss with extensive destruction, tissue necrosis, or damage to muscle, bone, or supporting structures (e.g., tendon, joint capsule). Undermining and sinus tracts also may be associated with Stage IV pressure ulcers.

The following limitations are inherent in these definitions:

1. Because the skin remains intact in Stage I pressure ulcers, these lesions are not ulcers in the usual sense. In addition, Stage I pressure ulcers are not always reliably assessed, especially in patients with darkly pigmented skin. A reliable system to accurately identify Stage I pressure ulcers in individuals with darkly pigmented skin should be developed. Despite these limitations, identification of a Stage I pressure ulcer is critical for indicating the need for more vigilant assessment and preventive care.
2. When eschar is present, a pressure ulcer cannot be accurately staged until the eschar is removed.
3. It may be difficult to assess pressure ulcers in patients with casts, other orthopedic devices, or support stockings. Routine assessment to check for adequate circulation, movement, and sensation may fail to detect pressure ulcers beneath casts. Health care providers should (1) assess the skin under the edges of casts, (2) be alert to patient complaints of pressure-induced pain, (3) determine whether casts need to be altered or replaced to relieve pressure, and (4) remove support stockings to assess the skin.

## Incidence and Prevalence

It has been difficult to determine both the incidence (new cases appearing during a specified period) and the prevalence (a cross-sectional count of the number of cases at a specified point in time) of pressure ulcers because methodological limitations have prevented researchers from drawing meaningful conclusions from available data. These problems exist in data available from acute care hospitals, long-term care facilities, and home care settings. The NPUAP Consensus Development Conference (NPUAP, 1989) broadly categorized the methodological barriers to interpreting the results of incidence and prevalence studies into three problem areas: (1) Study populations were not always comparable (e.g., data collected in tertiary care hospitals are not likely to reflect the findings in community hospitals); (2) sources of data ranged from direct observation of patients by trained research personnel to information retrieved from patient records; and (3) study methods often confused incidence and prevalence data, included ulcers at different stages, or excluded segments of the institutionalized population.

In hospital settings, the incidence of pressure ulcers has ranged from 2.7 percent (Gerson, 1975) to 29.5 percent (Clarke and Kadhom, 1988). Prevalence by hospital bed ranged from 4 percent (Ek and Boman, 1982) to 69 percent (Ameis, Chiarcossi, and Jimenez, 1980), whereas the prevalence by hospitalized patients varied between 3.5 percent (Shannon and Skorga, 1989) and 29.5 percent (Oot-Giromini, Bidwell, Heller, et al., 1989). In the most extensive study of acute care facilities, Meehan (1990) surveyed 148 hospitals and found that the prevalence of pressure ulcers was 9.2 percent.

Several special subpopulations may be at higher risk than the general hospital population for pressure ulcer formation. Richardson and Meyer (1981) reported a prevalence of 60 percent among hospitalized quadriplegic patients, and Versluysen (1986) found an incidence of 66 percent among elderly patients admitted for femoral fracture. Orthopedic patients may also be at high risk because they are often immobilized; patients with fractures appear to be at greater risk than those admitted for elective orthopedic procedures (Versluysen, 1985; Jensen and Juncker, 1987). Although few studies have focused on the critical care population, the 33-percent incidence reported by Bergstrom, Demuth, and Braden (1987) and the 41-percent prevalence reported by Robnett (1986) indicate that this group may also be at high risk.

Among persons in skilled care facilities and nursing homes, the prevalence ranged from 2.4 percent (Petersen and Bittmann, 1971) to 23 percent (Langemo, Olson, Hunter, et al., 1989; Young, 1989). Rates obtained in the few incidence studies in this population fall within a comparable range (Brandeis, Morris, Nash, et al., 1990; Langemo, Olson, Hunter, et al., 1991; Powell, 1989). The highly variable nature of case mix and staffing makes generalization concerning these results particularly difficult. According to Brandeis, Morris, Nash, et al. (1990), the incidence of pressure ulcers increases as the length of stay increases. The prevalence and incidence of pressure ulcers in these facilities deserve closer attention to determine the magnitude and cost of this problem and allow administrators to project the resources needed to increase the effectiveness of patient care.

The prevalence of pressure ulcers among persons cared for in the home with the supervision or assistance of professionals is not completely clear, and thus the magnitude of the problem in this population also requires further investigation. Barbenel, Jordan, Nicol, et al. (1977) reported a prevalence of 8.7 percent of ulcers designated Stage II or worse. In a relatively small sample (N = 30), Clarke and Kadhom (1988) reported an incidence of 20 percent in home care patients. A recent 1-year study of 326 home health care patients reported an incidence of 4.3 percent and a prevalence of 12.9 percent (Hentzen, Bergstrom, and Pozehl, 1993).

In summary, the incidence and prevalence of pressure ulcers are sufficiently high to warrant concern, yet it has been difficult to draw definitive conclusions about the nature and magnitude of this problem. Determining these rates has been complicated because many studies were not sufficiently controlled in terms of data acquisition methods and pressure ulcer classification systems. Studies that use large data bases suffer because the data acquisition skills of the observers are not controlled. Results of these studies must be balanced with results of studies involving smaller samples but having technically more accurate data acquisition methods.

To help correct these methodological problems, the staging system recommended by the NPUAP (1989) should be endorsed and used in future studies to allow the data to be compared and interpreted. In addition, a systematic assessment guide detailing the sites of the pressure ulcers should be used to prevent errors of omission in measurement. Information about the incidence and prevalence of pressure ulcers that takes into account the stage of the lesion, the type of health care facility, the specific diagnosis, the individual's level of mobility, and other risk factors will permit administrators to plan and allocate services to those populations at risk for this condition.

## Methodology for Guideline Development

The procedures followed for developing this guideline were those recommended by AHCPR and by Steven Woolf, MD, MPH, a consultant to the panel. The procedures were further influenced by consultation with JoAnne Horsley, PhD, RN, FAAN, the principal investigator for the Conduct and Utilization of Research in Nursing (CURN), a pioneering project in research utilization funded during the late 1970's. The CURN project developed practice protocols based on a critique of available research and a synthesis of current knowledge (Haller, Reynolds, and Horsley, 1979).

The panel used the methodology recommended by AHCPR to develop recommendations based on (1) the clinical benefits and harms of potential interventions and (2) relevant health policy issues. Assessment of the former was intended to determine which practices produce the best health outcome for patients in the aggregate sense, and assessment of the latter was intended to address resource constraints (e.g., costs of interventions) and feasibility issues that might affect implementation of the panel's recommendations.

This guideline offers recommendations about how health care professionals can provide quality care. The recommendations are based on current scientific evidence and professional judgment and do not determine whether selected procedures are reimbursable; decisions about reimbursement are made by third-party payers. Furthermore, the recommendations do not specify which professionals should perform which procedures; these decisions are based on professional qualifications and State licensing regulations.

Panel members were appointed by AHCPR based on a broad range of input from professional and health care consumer organizations and individuals. At least one professional organization endorsed each panel member. Over the course of this guideline's development, a total of 20 individuals served as panel members, with panel positions held at various times by seven physicians (family medicine, dermatology, plastic surgery, surgery-nutrition, gerontology, and physical medicine and rehabilitation), seven nurses (rehabilitation, aging, acute care, enterostomal therapy, wound care, nutrition, health care education, and management), one occupational therapist (rehabilitation), two biomedical engineers (rehabilitation), two basic scientists (wound healing), and one consumer representative. The panel also engaged a number of consultants with expertise in geriatric medicine, wound care research, nutrition, health economics, guideline development methodology, research utilization, clinical algorithm development, infection control, and consumer interests.

Traditionally, guidelines and standards have been based on the best judgments of a panel of experts. However, it is no longer deemed sufficient to rely on such judgments alone without a prior understanding of the scientific data base. Thus, the panel was charged with summarizing the scientific data to support guideline recommendations. The National Library of Medicine (NLM) conducted a comprehensive literature review based on panel requests, and panel members scrutinized evidence of clinical benefits or harms and reviewed prevailing practice as documented in professional standards and written reports. Retrieval of published manuscripts and relevant unpublished material was comprehensive. Relevant literature was identified through computerized searches of articles published between 1966 and May 1, 1993. MEDLARS was the primary data base searched, with supplemental data bases used as necessary. Literature was also identified through (1) hand searches of journals not referenced in computerized data bases; (2) reference lists from review articles; (3) personal files of panelists; (4) recommendations of peer reviewers, open forum participants, and companies manufacturing products used to treat pressure ulcers; and (5) research reports submitted by investigators engaged in pressure ulcer research. Through these mechanisms, the panel reviewed more than 45,000 abstracts (including duplicates from several data bases). About 1,700 manuscripts were selected for further evaluation based on the inclusion criteria established by the panel; 40 percent of these were research manuscripts. All research manuscripts, whether published or unpublished, were evaluated for quality and were included only if they met the quality standards and content-based inclusion criteria established by the panel. Eventually, 333 references were cited to support this guideline.

The guideline was written after the panel evaluated the scientific evidence and expert clinical opinion and considered the benefits and harms of each potential recommendation. Recommendations were based on the quality and quantity of supporting research evidence (either direct or indirect) indicating that a certain action would produce a favorable result. In the absence of conclusive research evidence, expert opinion was sought and documented as such. Expert opinion (as reflected in review articles, textbooks, the standards and guidelines set by professional organizations, and the judgment of panel members and peer reviewers) is an important part of guideline development because it is unlikely that an adequate scientific data base will exist to support every recommendation.

The experience of the CURN project showed that guidelines are most effective when they are specific (Haller, Reynolds, and Horsley, 1979). For this reason, the panel attempted to be as specific as possible while allowing enough flexibility to respect expert judgment and patient preferences in individual cases.

Following completion of an outline of the guideline document, an open forum was announced in the Federal Register and was held in Washington, DC, on April 9, 1992. All persons, organizations, and agencies with an interest in the pressure ulcer treatment guideline were invited to attend and to present written or verbal testimony. A draft version of the document was then presented at a conference held on March 5-6, 1993, sponsored by the NPUAP and WOCN and attended by more than 300 persons. This conference enabled all participants to provide feedback on the content and format of the document through formal response and a computer-assisted critique. Conference sessions were also held in which individuals representing acute care, long-term care, and home care settings provided input.

Next, an additional formal peer review was undertaken. Peer reviewers were selected from the following groups:

1. Professional organizations. These organizations were invited to disseminate the guideline to as many reviewers as deemed appropriate and to collate responses in order to submit to the panel a single document containing reviewer comments.
2. Participants in the open forum and NPUAP and WOCN conference as well as other professional participants who volunteered.
3. Government regulatory agencies. Copies of the guideline were sent to the Health Care Financing Administration, the FDA, and the CDC. Several individuals within these agencies served as peer reviewers; however, their review does not constitute official agency review and approval.
4. Interested health care providers and consumers who expressed to the panel chair or panel members their willingness to review the guideline.

A list of potential peer reviewers was maintained throughout the project. Those finally selected represented a broad range of professional disciplines, clinical practice arenas, and geographic regions. Peer review by professional organizations and Government regulatory agencies does not constitute endorsement of the guideline. Peer reviewers were asked specifically to evaluate (1) the comprehensiveness of the literature review and identify any literature evidence that was omitted or inappropriately or incompletely cited, (2) the conclusions based on the literature review and analysis, and (3) the guideline recommendations based on practical realities. Their comments were distributed to panel members, whose subsequent deliberations led to revisions of the guideline.

The panel also subjected the pressure ulcer treatment guideline to pilot review, which comprised three specific activities. First, health care agencies were invited to examine the hypothetical impact of the guideline on their setting in terms of cost, resources, and practicability. Second, health care agencies were invited to examine the guideline, test it informally on a small number of patients in the practice setting, and provide feedback to the panel. Third, selected sites were asked to provide a somewhat more formal evaluation of the guideline, as time allowed, setting in motion a plan for implementing guideline recommendations. Such in-depth testing provided additional useful information prior to final revisions.

Pilot review sites, like peer reviewers, were selected from a list of names submitted to the panel during the process of guideline development. Key organizations representing various classifications of health care settings were asked to conduct pilot reviews. A broad diversity of clinical representation was sought. University, community, and small rural hospitals were selected as well as nursing home chains, small private nursing homes, and visiting-nurse and other home health care agencies. Attention was also given to the geographic distribution of pilot reviewers.

The results of peer and pilot review were collated, and appropriate suggestions were incorporated into the guideline. The revised guideline was then submitted to AHCPR for publication.

## Strength-of-Evidence Ratings

The panel assigned each recommendation a rating of A, B, or C to indicate the strength of the evidence supporting the recommendation. The ratings were based on the following criteria:

1. Results of two or more randomized controlled clinical trials on pressure ulcers in humans provide support.
2. Results of two or more controlled clinical trials on pressure ulcers in humans provide support, or when appropriate, results of two or more controlled trials in an animal model provide indirect support.
3. This rating requires one or more of the following: (1) Results of one controlled trial; (2) results of at least two case series/descriptive studies on pressure ulcers in humans; or (3) expert opinion.

This approach was adapted from Guide to Clinical Preventive Services by the U.S. Preventive Services Task Force (1989). Evidence ratings are based on the number of studies (quantity), quality of research, number of replications, and consistency of findings.

It is important to clarify that these ratings represent the strength of the supporting research evidence, not the strength of the recommendation itself. The strength of each recommendation is conveyed in the language used to describe it. For example, the panel's directive to "cleanse wounds initially and at each dressing change" leaves little doubt that this measure is strongly recommended as a time-honored, efficacious treatment, despite an evidence rating of C. On the other hand, the recommendation to consider electrical stimulation therapy under certain conditions is less directive, despite stronger supporting research evidence. Although electrical stimulation has been shown to enhance the rate of healing in clinical trials, it is a relatively new technology that has not been used extensively in clinical practice.

## Economic Impact and Public Policy Implications

The eventual economic impact of the utilization of the guideline's recommendations is difficult to determine. Miller and Delozier (1994) estimated the baseline costs of pressure ulcer treatment under two scenarios. Although the data bases used by these investigators have limitations such as underreporting of pressure ulcers and approximations of physician fees rather than actual costs, this study provides a reasonably accurate estimate of the costs of pressure ulcers in 1992.

According to this analysis, the mean hospital charge for patients with a primary diagnosis of pressure ulcers was $21,675, and estimated physician charges were $2,900 per case. The total charges for 34,000 inpatients with a primary diagnosis of pressure ulcer were $836 million. To illustrate the costs of pressure ulcers as a secondary diagnosis, hip fracture patients with and without pressure ulcers were compared. An average of $10,986 in additional hospital charges was attributed to the pressure ulcers. When estimated physician fees of $1,200 per case were included, the total cost of pressure ulcers as a complication of hip fracture was $84 million. Although less specific cost data are available for nursing home facilities and home care settings, Miller and Delozier conservatively estimate that the 1992 costs of pressure ulcer care in these settings was $355 million and $60 million, respectively. The total estimated cost for all settings was $1.335 billion.

The economic impact of guideline implementation was estimated by comparing the costs of care recommended by the guideline with the cost of the care that is currently provided. Although in some cases the costs of initial services (e.g., more complete assessments, frequent repositioning, thorough wound cleansing) would increase, these costs are minimal when compared with the costs of the more intensive care required to treat large or recalcitrant pressure ulcers. Guideline implementation should save money by reducing the need for high acuity care, expensive equipment, and special procedures while minimally increasing the funds dedicated to "low tech care" (e.g., provision of adequate personnel to feed and turn patients). Although it is difficult to assess the magnitude of savings, Miller and Delozier suggest that guideline implementation is likely to save at least $40 million (or 3 percent) of the total costs measured by their analysis.

One policy question raised by this analysis is whether committing more resources to the prevention and initial care of pressure ulcers with the expectation of avoiding the higher human and economic costs of treating more advanced ulcers would be feasible and advantageous. In the interest of ensuring high-quality, cost-effective patient care, this question warrants serious consideration by consumers, care providers, third-party payers, and Government regulatory agencies.

## Followup Activities

Recommendations for followup activities should focus on expanded programs of research in this area. Monitoring the incidence and prevalence of pressure ulcers at various stages and in various settings would help in evaluating the impact of the pressure ulcer prevention and treatment guidelines. Such studies should use the standard pressure ulcer classification system recommended in this document. A reliable system to accurately identify Stage I pressure ulcers in individuals with darkly pigmented skin should be developed.

Research is needed regarding the assessment and management of pressure ulcer pain and the relationship between psychosocial status and healing. Continued monitoring of the results of studies in which cytokine growth factors are being used to promote healing, as well as studies on the efficacy of electrical stimulation, would be beneficial. The use of clean rather than sterile dressings warrants further investigation. The panel would also like to see continued investigation of the extent of use and efficacy of various types of support surfaces, both static and dynamic. In addition, multisite controlled clinical trials comparing surgical and medical management of pressure ulcers should be conducted. One important part of such studies should be an analysis of costs.

Ideally, "healing" is the outcome that should be measured in pressure ulcer treatment studies. Studies measuring intermediate outcomes (such as partial healing or a decrease in the size of the ulcer) make more limited contributions to the scientific data base. All treatment studies should carefully describe the usual care that is administered to control subjects.

Several programmatic changes were recommended by the panel, such as more extensive formation of quality improvement teams and educational programs and greater use of nutritional assessment instruments and nutritional supplementation. Evaluating the application of these recommendations will advance knowledge in this field.

## Organization of the Guideline

This guideline is organized to correspond with the pertinent aspects of pressure ulcer care: Assessing the pressure ulcer and the patient; managing tissue loads; caring for the ulcer; managing bacterial colonization and infection; repairing ulcers surgically; providing education for patients, families, and caregivers; and improving the quality of care through quality improvement programs. The guideline reflects the state of current knowledge, as contained in the health care literature, regarding the effectiveness and appropriateness of procedures and practices designed to treat pressure ulcers. In the Clinical Practice Guideline, the panel provides recommendations for the treatment of pressure ulcers along with a synopsis of evidence supporting each recommendation. The guideline recommendations alone, without the supporting evidence, can be found in the Quick Reference Guide for Clinicians. A more complete discussion of relevant research as well as tables summarizing the evidence appears in the full Guideline Technical Report. Finally, a Consumer Version is available in English and Spanish.

## Clinical Algorithm

The overview algorithm in Figure 1 provides the clinician with a visual display of the conceptual organization, procedural flow, decision points, and preferred management pathways discussed in the guideline. When applied to individual patients, this algorithm should be adapted to accommodate patient preferences and overall patient goals. Numbers in the algorithm correspond to the explanations that follow it. Subalgorithms that expand on nutritional assessment and support, management of tissue loads, ulcer care, and management of infection have been incorporated within the relevant chapters of this document. The various shapes in all algorithms have the following meanings: (1) Diamonds designate "yes-no" decisions; (2) rectangles designate interventions; (3) hexagons designate the need for patient education and counseling; and (4) ovals refer the reader to previous nodes in the algorithm.

Figure 1. Management of Pressure Ulcers: Overview

### 1. Pressure Ulcer Identification

The pressure ulcer treatment guideline provides recommendations concerning the evaluation and management of patients with established Stage II, III, and IV pressure ulcers. A separate guideline (Pressure Ulcers in Adults: Prediction and Prevention. Clinical Practice Guideline, No. 3) describes strategies for identifying high-risk patients, preventing ulcers, and treating Stage I pressure ulcers.

### 2. Initial Assessment

The initial assessment of patients with pressure ulcers has several dimensions: (a) Assessment of the pressure ulcer, (b) complete history and physical examination, (c) assessment for complications and comorbidities, (d) nutritional status assessment, (e) pain assessment, (f) psychosocial evaluation, and (g) assessment of risk for developing additional pressure ulcers.

An assessment of the pressure ulcer should determine the location, stage, size, and depth of the wound, as well as the presence or absence of sinus tracts, undermining, tunneling, exudate, necrotic tissue, epithelialization, and granulation tissue. The history and physical examination should address concurrent illnesses and conditions that might affect wound healing, including nutritional deficits and neurological, vascular, endocrine, or immunological abnormalities. The psychosocial evaluation should focus on the patient's cognitive capacities and ability to help develop and adhere to treatment plans. The extent of social support should be assessed, with arrangements made to provide assistance with home care if needed. In addition, the degree of pain produced by the ulcer should be evaluated and appropriate steps taken to minimize any pain or discomfort. (Readers are referred to the AHCPR-sponsored guideline, Acute Pain Management: Operative or Medical Procedures and Trauma. Clinical Practice Guideline, No. 1.) Patients judged to be at high risk for additional pressure ulcers should be identified and appropriate precautions taken. (Refer to Pressure Ulcers in Adults: Prediction and Prevention. Clinical Practice Guideline, No. 3.)

### 3. Education and Development of Treatment Plan

After the initial assessment is completed, patients and family caregivers should be provided with information sufficient to enable them to understand the treatment of pressure ulcers and assist in developing a treatment plan.

The treatment plan should reflect the patient's values and explicitly define the goals of therapy. In general, the primary goal is healing of the ulcer, but sometimes the goal of patient comfort may take precedence. An example might be the patient with a terminal medical condition who experiences pain or agitation on turning or during administration of tube feedings (to correct malnutrition); another patient may simply wish to forgo the sort of intensive management that may be required to heal advanced pressure ulcers. Although the recommendations in this guideline apply primarily to patients for whom the goal of therapy is wound healing, they are also applicable, in whole or in part, to patients seeking palliative care.

An effective pressure ulcer treatment plan should have three components: (a) Nutritional assessment and support, (b) management of tissue loads, and (c) ulcer care and management of bacterial colonization and infection. These three treatment components are equally important and essential aspects of pressure ulcer management. As can be seen in the algorithm in Figure 1, these three issues should be addressed simultaneously.

### 4. Nutritional Assessment and Support

(See Figure 2 in Chapter 2, Assessment.) Nutritional assessment is essential for identifying individuals whose nutritional status may compromise healing. Assessment also serves as a basis for planning nutritional support.

Figure 2. Nutritional Assessment and Support

### 5. Management of Tissue Loads

(See Figure 3 in Chapter 3, Managing Tissue Loads.) Management of tissue loads (i.e., pressure, friction, and shear) is a critical component of any pressure ulcer treatment plan.

Figure 3. Management of Tissue Loads

### 6. Ulcer Care

(See Figure 4 in Chapter 4, Ulcer Care, and Figure 5 in Chapter 5, Managing Bacterial Colonization and Infection.) Care of the pressure ulcer involves debridement, wound cleansing, the application of dressings, and measures to control bacterial colonization and treat infection.

Figure 4. Ulcer Care

Figure 5. Managing Bacterial Colonization and Infection

### 7. Assessment of Ulcer Healing

Progress toward healing should be evaluated at least weekly. If signs of ulcer deterioration are observed sooner (e.g., during daily dressing changes), steps to reverse them should be taken immediately. If the patient's general condition deteriorates (e.g., signs of sepsis), the ulcer should be reassessed promptly. Healing should be evaluated using the same criteria discussed under initial assessment (Node 2), that is, size, depth, and the presence of exudate, epithelialization, granulation tissue, and findings such as necrotic tissue, sinus tracts, undermining, tunneling, and purulent drainage or other signs of infection. A clean pressure ulcer with adequate innervation and blood supply should show progress toward healing in 2 to 4 weeks.

### 8. Monitoring

Healing ulcers should be assessed regularly to ensure continued progress toward the goal of complete healing. Caregivers should continue to monitor the individual's general health, nutritional adequacy, psychosocial support, and pain level and should be alert to signs of complications (e.g., advancing cellulitis, sinus tract or abscess, meningitis, endocarditis, septic arthritis, osteomyelitis, sepsis). The frequency of monitoring should be determined by the clinician based on the condition of the patient, the condition of the ulcer, the rate of healing, and the type of health care setting.

### 9. Reassessment of Treatment Plan and Evaluation of Adherence

If the ulcer is not healing, the clinician must reassess the treatment plan and determine whether it is being followed. If necessary, the plan and strategies for its implementation should be revised. In particular, the clinician should assess whether tissue load management is adequate and should evaluate the extent of adherence to cleansing, dressing, and nutritional support interventions. Necrotic tissue or underlying abscesses should be suspected if the ulcer is not healing, and if found, removed or drained. Evaluation and treatment of pressure ulcer infection and underlying osteomyelitis should also be undertaken.