# Attachment C. Patient Discussion Handouts

## Explanation of Handouts

Four discussion handouts for patients are provided. They are sufficiently specific to address a full range of patient concerns. The patient's focus tends to change during treatment. Early concerns may focus on comfort, or fear of potentially dangerous causes of low back pain. Later, questions about special studies, procedures, and diagnoses may arise. The few patients having trouble overcoming their activity limitations may have to consider the relative benefits either of conditioning more vigorously or of changing their activity goals. These handouts are not intended to stand alone for all patients. Rather, they are designed to foster the clinician's discussions with patients about important issues, as needed.

- The first discussion handout is intended to prepare the patient for treatment recommendations. It can be provided to all patients if no serious condition is detected (probably at the first visit).
- The second discussion handout, which is only useful for the 10 percent of patients who are slowest to recover, helps patients understand about the use of special studies and the potential for diagnostic confusion.
- The third discussion handout is for the same 10 percent of patients when they are facing further treatment. It helps the patient understand the change in focus from merely treating symptoms and avoiding debilitation to building activity tolerance through safe exercises.
- The last discussion handout is only for those patients who, for whatever reasons, are experiencing difficulties in overcoming their activity limitations. It allows the clinician to help the patient develop an understanding of available options. If the patient is failing to overcome his or her limitations and seeks no other alternatives, the clinician has an avenue to further address potential nonphysical (e.g., psychological and socioeconomic) pressures that can accompany activity limitations due to low back symptoms.

## C1. Handout 1: Back problems?

### The news is good

Your clinician has not found any dangerous causes for your back problem. Almost everyone has a low back problem at some time. In only one person out of 200 does the problem have a serious cause. A medical history and physical examination alone are very good at detecting these uncommon cases.

### You should recover soon

Nine out of 10 persons with low back problems recover within 1 month, and most recover even sooner. Therefore, an x-ray of your back or other tests at this time would only waste your time. If your recovery happens to be slower than normal, your clinician will then look further for a reason.

Even with back symptoms, you may be able to continue your usual activities. But you might have to slow your pace. Strenuous activity or heavy lifting could give you trouble. If you work outside the home, much depends on the kind of work you do. Office work may require few changes. On the other hand, if your job involves heavy labor-like a furniture mover-you will probably have trouble working as usual right away.

Age also makes a difference. As we age, so do our spines. Activities that require speed and strength become harder to do. This happens to many people by age 30, to most people by age 40, and to nearly everyone by age 50. Consider your age as you plan your daily tasks when recovering from a back problem.

### You can ease your discomfort safely

Your clinician will suggest safe ways for you to be more comfortable as you recover. But staying in bed is usually not the best thing. More than a few days in bed actually weakens your back and could cause your symptoms to last longer. Neither bed rest, medications, or any other remedies should be expected to do away with all the discomfort. It is important to be up and around as much as possible even if you are uncomfortable. The sooner you return to normal daily activities, the sooner your symptoms will disappear.

### You may need to make changes in your daily activities

Sitting may not be comfortable. Sitting is not dangerous, but it puts more stress on the back than standing. While recovering, try to spend less time sitting. To make sitting easier, support the curve of your lower back with a towel or small pillow. If possible, use a chair or other seat with a slightly reclining back.

#### Lifting

Keep anything you must lift close to the belly button. Lifting a carton of milk or orange juice at arm's length can stress your back more than lifting 30 pounds held close to the body. Also try not to bend forward, twist, or reach when lifting.

#### Exercising can help your back

Your health care provider may suggest safe exercises such as walking, swimming, or riding a stationary bike. If done correctly, these exercises do not stress the back any more than does sitting on the side of your bed (which is not dangerous). What exercising does is keep your back muscles from becoming weakened by not enough activity. In addition, exercise is good for your general health, can speed your recovery, and may help protect you from future back problems. As your symptoms lessen, daily exercise will make it easier for you to resume your normal activities.

Points to remember:

- There is no hint of a serious problem.
- Your back symptoms are the kind that usually disappear within a month. Expect a rapid recovery.
- No medications or other treatments, including home remedies, can be expected to relieve all the discomfort immediately.
- You may need to change some daily activities to keep from irritating your back. But stay active enough to keep from weakening your muscles.
- If you are one of the few who is slow to recover, your clinician will look for the reason. Even if you are slow to recover, there is little chance of a serious reason for your back problem.

## C2. Handout 2: Seeking a reason for slow recovery...

### Special tests may be needed

If your back problem is slow to recover, your health care provider may consider special studies (tests) to find the reason. They may include blood tests; or an imaging study may be needed to view your spine. Nerve tests may help identify certain leg problems. The chances are good that your problem will not be serious. In only one person out of 200 do low back problems have a serious cause.

### Why wait to do special studies?

You may have read or heard of tests like MRI, CAT scan, or myelogram. These are special imaging studies. They use special equipment to provide different views of body structures like your spine. You may wonder why your health care provider did not order these tests in the first place. There is a good reason. Imaging studies can be confusing. By themselves, they cannot tell the difference between possible causes of a back problem and common changes in the spine because of aging.

As we grow older, the spine changes. Almost half the population has aging changes in the spine as early as age 35. Yet most people who have such changes will not have a back problem lasting longer than 1 month. Remember that nine out of 10 people who have low back problems recover within 1 month. For these persons, imaging studies are unnecessary and confusion can be avoided. The tests could show a condition that is really not a problem and has no connection to back symptoms.

Imaging studies are seldom used alone. Surgery is never based on imaging studies alone. The studies could find something that is not really the cause of your problem. Before deciding whether imaging studies are needed, your health care provider should review your physical examination carefully. He or she may also do other kinds of tests to find evidence of a problem. Ask your health care provider to explain what tests are needed for you.

Table 1 lists a number of terms that are commonly used to describe (diagnose) the cause of low back symptoms. However, scientific studies have not been able to show a connection between these diagnoses and back symptoms. In addition, there is no evidence that these conditions benefit from surgery or other specialized forms of treatment.

Handout C2: Table 1. Common diagnosis used to explain back symptoms

Annular tear | Adult spondylolysis | Myofascitis
Fibromyalgia | Disc syndrome | Strain
Spondylolysis | Lumbar disc disease | Facet syndrome
Degenerative joint disease | Sprain | Osteoarthritis of the spine
Disc derangement/disruption | Dislocation | Subluxation

### When is surgery a choice?

If your back symptoms affect your legs and are not getting better, a herniated lumbar disc (what many people call a slipped disc) may be the reason. The disc can press on a nerve root in your back and can either irritate the nerve or affect its function. If tests show strong evidence that this is happening, surgery to take the pressure off of the nerve may speed your recovery.

If your health care provider tells you that surgery is a possibility, ask about your choices. Ask what would happen without surgery. Before agreeing to surgery, get a second opinion from another health care provider. Also, ask about the tests that were done to suggest that surgery is the best approach for your back symptoms. Table 2 lists some conditions or diagnoses that sometimes benefit from surgery or other special treatment.

Handout C2: Table 2. Diagnoses that may benefit from surgery or other treatment

"Leg pain due to herniated lumbar disc".; - Surgery is sometimes used to relieve the pressure on the nerve and can speed recovery if the diagnosis is based on strong evidence. Surgery should no be expected to make the back brand new.
"Leg pain due to spinal stenosis."; - Spinal stenosis is an uncommon cause of walking limitation in the elderly. It is very rare under the age of 60. Surgery to take pressure off the nerves can improve walking distance and leg pain.
"Leg pain with spondylolisthesis."; - Spondylolisthesis is measurable slippage of one vertebra upon another. In extremely rare cases, the slippage may be great enough to affect nerve root function. Surgery is sometimes used to take pressure off of the nerve and to fuse the vertebrae to prevent future slippage.
"Fracture or dislocation."; - Surgery is commonly used to repair a fracture or dislocation if the fracture or dislocation affects the spinal nerves
"Spinal arthritis."; - If the condition is verified by a positive blood test and is not osteoarthritis or degenerative joint disease, nonsteroidal antiinflammatory drugs (NSAIDs), such as ibuprofen, may be used

### Tests cannot always tell you the cause of your symptoms

Medical science cannot always explain the exact cause of most common low back symptoms. But medical science is very good at finding out if you have a dangerous condition causing your symptoms. If your problem is not caused by a serious condition, you can continue looking forward to recovery.

### Exercise is important

Remember to continue to exercise as you were instructed by your health care provider and as described in Handout 1. It is important not to neglect your muscles. Exercise regularly!

Points to remember:

- Special studies are not needed for early detection and care of low back problems.
- Special studies can mislead if used alone. They can give additional information about a problem if used with other evidence.
- If your health care provider suggests surgery, ask what the evidence is for surgery. Ask about your choices and what would happen without surgery. Get a second opinion from another health care provider. Your surgeon will understand how important it is for you to be sure.

## C3. Handout 3: Overcoming your back problem

By now your health care provider has given you the news that you can comfortably begin to get back to your daily activities. Even if you required surgery, you can now safely begin a specific, gentle exercise program to condition your body and your back muscles. This program will increase your back's ability to help you do the things you want and need to do.

Start with a simple, safe exercise such as walking, stationary bicycling, or swimming to build your general stamina. If you have been inactive, you may need to begin slowly and gradually increase your activity each day. Your health care provider will make specific recommendations for safe exercises that do not stress your back any more than sitting on the side of your bed. Exercise helps because it:

- Trains the muscles that protect your back.
- Conditions your whole body.
- Stimulates the body to make its own powerful pain killers.
- Allows you to do more things more comfortably.

You also will find out what you can do easily and what takes more effort.

### Reality about back problems

Although your recovery seems slow, your symptoms will continue to decrease unless you are inactive. However, your back may never feel as young as it once did. This happens to many of us by age 30, most by age 40, and just about everyone by age 50. Back problems often are the first sign of aging. You may have noticed that few professional athletes can continue competing beyond age 40. While some people may be able to resume strenuous activity after back problems as they get older, it usually needs to be at a slower pace. Most people need to shift gears and make changes in goals and activities as they grow older. Even at a slower pace, exercise will help you to be able to tolerate more of your daily activities.

Once you have had an activity-limiting back problem that lasts more than a few weeks, there is a 40 to 60 percent chance of having another back problem within the next few years. However, symptoms usually are not as severe in future episodes as in the first episode.

### Success

As you begin to recover, the goal is to try to prevent back problems from returning or, if they do return, being severe. Success will depend upon two factors. The first is the condition of your protective muscles. The second is the activities you ask your back to tolerate.

Ignoring either of these factors usually means more back problems. For example, a coal miner can expect further problems because mining is so demanding on the back. By contrast, a member of royalty who never needs to stress his or her back but does no conditioning exercises also can expect regular back problems. How well YOU do in the future will depend on what kind of condition you are in and what you ask your back to do. The more easily you and your protective muscles tire, the greater the chance that your symptoms will return. Taking action to condition the protective muscles of your back can reduce your future problems.

### Safe exercises that are good for you and your back

Although exercises such as walking, stationary bicycling, or swimming are safe, you may feel some discomfort when you first start. After muscles become better conditioned, the soreness goes away. For example, during the winter when the weather is bad and many of us might stay indoors and be less active, the muscles of the back can lose their conditioning. When the first day of spring arrives and many of us go out to garden, the back may begin to ache when the out-of-condition protective muscles easily tire. Continuing such work daily over a few days or weeks reconditions the protective muscles so that they don't tire quite so easily, and the soreness disappears.

Remember that an increase in discomfort in an already painful back is common. But safe exercises (that involve less stress on the back than sitting on the side of the bed) should not harm your back. The shorter the time since beginning the conditioning, the greater the chance of increased soreness.

### Conditioning requires regular activity

Regular activity is essential to obtain the conditioning effect to protect your back. Conditioning is achieved by building up to 30 minutes of continuous walking, stationary cycling, or swimming at a targeted heart rate (Table 1) or through jogging for 20 minutes. Conditioning works best if combined with your normal, daily activities both at home and at work. Stay as active as possible and exercise every day.

Handout C3: Table 1. Building exercise tolerance

1. Try to maintain your daily activity as close to your normal level as possible.; 2. As soon as possible begin walking, riding a stationary bicycle, or swimming. Choose what works for you.; 3. Gradually build up to 30 minutes of activity without stopping.; 4. Once you can tolerate 30 minutes of activity, establish a target heart rate that will help you to condition your muscles, heart, and respiratory system.; 5. Then, your health care provider may also recommend some exercises for your back muscles

Your health care provider may have suggested ways to modify your daily chores to reduce the chance of irritating your back. Such changes at home or work are usually temporary. They are intended to give you time to improve the condition of your protective back muscles so that you can resume most normal activities. Table 2 offers guidelines to your health care provider on work recommendations to allow you reasonable time to recondition your back. Long-term activity tolerance varies greatly from person to person. Age and overall health are important factors, too. Regular, mild exercise may be enough for some. Others may be able to return to vigorous activities at a slower pace.

Handout C3: Table 4. Guidelines for sitting and unassisted lifting

| Symptoms
| Severe | Moderate | Mild | None
Sitting[1] | 20 min | | | 50 min.
Unassisted lifting[2]
Men | 20 lbs | 20 lbs | 60 lbs | 80 lbs
Women | 20 lbs | 20 lbs | 35 lbs | 40 lbs

Points to remember:

- Both your level of physical conditioning and the stresses you put on your back will determine how often you will have problems and how severe they become.
- Conditioning usually requires daily work and commitment.
- Be sure your activity goal is realistic and you know what it will take to achieve it. Once you are over your back symptoms, or after a month of general conditioning training, your health care provider may suggest that you begin doing back muscle, trunk, or extremity exercises to gain further tolerance for specific tasks.
- If you have great difficulty resuming your previous daily routine, you may need to consider whether your old routine is realistic for you now.

## C4. Handout 4: When exercise is not helping

By now, your health care provider has made every effort to seek a medical reason for your continued activity limitation. You are well into the exercise program intended to condition your back for the activities you need to do. Unfortunately, for some people success is less easy and slower to achieve. If this is the case, there are many things to consider.

### Age is important

Few middle-aged persons have a back that is as strong as it was at age 18. Medical science presently cannot reverse the aging process that limits activities requiring both speed and strength. Young people may find it hard to accept these limitations. Older people commonly find it difficult to give up or alter activities they have been doing for a long time.

Some people continue to look for a cure when progress is slow. Such efforts rarely succeed. Consider a basketball star like Larry Bird. Money was surely no object in seeking a cure for his back problem. He could afford the most expensive medical care and conditioning programs. Nevertheless, he was forced to retire at age 34. His back could no longer tolerate the physical stress of basketball.

How many athletes in strenuous sports can compete beyond age 35 or 40? Very few! Most of us must adjust our activities as we age, regardless of occupation or level of physical conditioning, many by age 30, most by age 40, and just about all of us by age 50. Some people can continue strenuous activities into their older years, especially if they are able to do it at their own pace. Others may need to consider change.

### Be realistic

Ask yourself three key questions about your daily activity requirements:

- Can a reasonable exercise program overcome my back problem?
- Will it be possible to continue a more time-consuming exercise program and my usual daily requirements long term?
- Is there any way I can change my activity requirements now or in the future?

If a reasonable exercise program is not helping you, there are several options: (1) You can choose to put up with discomfort and expect some setbacks. (2) You can begin a more time-consuming conditioning program. (3) You can change the pace of doing difficult activities. This may include a job change. People may use a combination of the three approaches.

Considering a job change is difficult, especially if back problems continue to limit your ability to do your work. Again, ask yourself this important question: "Is my activity goal realistic, or do I need to look at my options?" A review now might help you avoid a similar dilemma in the near or distant future, when increased age may work against you. Being a few years older sometimes makes a big difference in the chance of changing jobs. Some creative planning could benefit you now, or in the future, especially if your job activities present a problem.

When considering a job or career change, it is important to gather information from many sources. Some possibilities include private career counselors, local or State employment offices, and veterans' or consumer groups. You may also want to talk to someone working in the field.

### Information is your ally

Whether or not you explore job opportunities alone or with professional help, remember this important point:

- Only you can find a way to adjust your life, your job, or your plans in a way that is right for you.