# Attachment B. Pain Assessment Instruments

## B1. Visual analog scale

## B2. Pain drawing