# Attachment A. Algorithms

## A1. Initial assessment of low back symptoms

## A2. Treatment of acute low back problems on initial and followup visits

## A3. Evaluation of the slow-to-recover patient limitations >4 weeks)

## A4. Surgical considerations for patients with persistent sciatica

## A5. Further care of acute low back problems