# References

1. Andersson GBJ. The epidemiology of spinal disorders. In: Frymoyer JW, editor. The adult spine: principles and practice. New York: Raven Press, Ltd.;1991. p.107-46.
2. Vällfors B. Acute, subacute and chronic low back pain: Clinical symptoms, absenteeism and working environment. Scand J Rehab Med Suppl 1985;11:1-98.
3. Sternbach RA. Survey of pain in the United States: The Nuprin pain report. Clin J Pain 1986;2(1):49-53.
4. Cunningham LS, Kelsey JL. Epidemiology of musculoskeletal impairments and associated disability. Am J Public Health 1984;74:574-9.
5. Cypress BK. Characteristics of physician visits for back symptoms: A national perspective. Am J Public Health 1983 Apr;73(4):389-95.
6. Spengler DM, Bigos SJ, Martin NA, Zeh J, Fisher L, Nachemson A. Back injuries in industry: a retrospective study. I. Overview and cost analysis. Spine 1986 Apr;11(3):241-56.
7. Kelsey JL, White AA 3d. Epidemiology and impact of low-back pain. Spine 1980 Mar-Apr;5(2):133-42.
8. Nachemson AL. Newest knowledge of low back pain. A critical look. Clin Orthop 1992;279:8-20.
9. Deyo RA, Cherkin D, Conrad D, Volinn E. Cost, controversy, crisis: low back pain and the health of the public. Annu Rev Public Health 1991;12:141-56.
10. Keller RB, Soule DN, Wennberg JE, Hanley DF. Dealing with geographic variations in the use of hospitals: The experience of the Maine medical assessment foundation orthopaedic study group. J Bone Joint Surg 1990 Oct;72A(9):1286-93.
11. Volinn E, Mayer J, Diehr P, Van Koevering D, Connell FA, Loeser JD. Small area analysis of surgery for low-back pain. Spine 1992;17(5):575-81.
12. Bigos SJ, Battié MC. Acute care to prevent back disability. Ten years of progress. Clin Orthop 1987 Aug;(221):121-30.
13. Waddell G. A new clinical model for the treatment of low-back pain. Spine 1987 Sep;12(7):632-44.
14. Goertz MN. Prognostic indicators for acute low-back pain. Spine 1990 Dec;15(12):1307-10.
15. Von Korff M, Deyo RA, Cherkin D, Barlow W. Back pain in primary care: outcomes at 1 year. Spine 1993 Jun;18(7):855-62.
16. Kelsey JL. Idiopathic low back pain: magnitude of the problem. In: White AA; Gordon SL, editors. American Academy of Orthopaedic Surgeons Symposium on idiopathic low back pain. St. Louis, Toronto, London: C.V. Mosby Company; 1982. p. 5-8.
17. Field MJ, Lohr KN, editors. Guidelines for clinical practice: from development to use. Washington, D.C.: National Academy Press; 1992. 426 p.
18. Woolf SH. AHCPR interim manual for clinical practice guideline development. U.S. Department of Health and Human Services; 1991 May. AHCPR Pub. No. 91-0018.
19. Quebec Task Force on Spinal Disorders. Scientific approach to the assessment and management of activity-related spinal disorders. A monograph for clinicians. Report of the Quebec Task Force on Spinal Disorders. Spine 1987;12(7S):S1-S59.
20. Aejmelaeus R, Hiltunen H, Härkönen M, Silfverhuth M, Vähä -Tahlo T, Tunturi T. Myelographic versus clinical diagnostics in lumbar disc disease. Arch Orthop Trauma Surg 1984;103(1):18-25.
21. Aiello I, Serra G, Migliore A, Tugnoli V, Roccella P, Cristofori MC, Manca M. Diagnostic use of H-reflex from vastus medialis muscle. Electromyogr Clin Neurophysiol 1983;23:159-66.
22. Bosacco SJ, Berman AT, Garbarino JL, Teplick JG, Peyster R. A comparison of CT scanning and myelography in the diagnosis of lumbar disc herniation. Clin Orthop 1984 Nov;(190):124-8.
23. Cats-Baril WL, Frymoyer JW. Identifying patients at risk of becoming disabled because of low-back pain. The Vermont Rehabilitation Engineering Center predictive model. Spine 1991 Jun;16(6):605-7.
24. Charnley J. Orthopaedic signs in the diagnosis of disc protrusion with special reference to the straight-leg-raising test. Lancet 1951 Jan 27;1:186-92.
25. Christodoulides AN. Ipsilateral sciatica on femoral nerve stretch test is pathognomonic of an L4/5 disc protrusion. J Bone Joint Surg [Br] 1989 Jan;71(1):88-9.
26. Deyo RA, Diehl AK. Cancer as a cause of back pain: frequency, clinical presentation, and diagnostic strategies. J Gen Intern Med 1988 May-Jun;3(3):230-8.
27. Giles LGF, Taylor JR. Low-back pain associated with leg length inequality. Spine 1981;6:510-21.
28. Grundy PF, Roberts CJ. Does unequal leg length cause back pain? A case-control study. Lancet 1984 Aug 4;2(8397):256-8.
29. Gunn CC, Milbrandt WE, Little AS, Mason KE. Dry needling of muscle motor points for chronic low-back pain. A randomized clinical trial with long-term follow-up. Spine 1980 May/Jun;5(3):279-91.
30. Herron LD, Turner J. Patient selection for lumbar laminectomy and discectomy with a revised objective rating system. Clin Orthop 1985 Oct;199:145-52.
31. Hudgins WR. The crossed straight leg raising test: a diagnostic sign of herniated disc. J Occup Med 1979 Jun;21(6):407-8.
32. Jensen OH. The level-diagnosis of a lower lumbar disc herniation: the value of sensibility and motor testing. Clin Rheumatol 1987 Dec;6(4):564-9.
33. Jensen OH, Schmidt-Olsen S. A new functional test in the diagnostic evaluation of neurogenic intermittent claudication. Clin Rheumatol 1989 Sep;8(3):363-7.
34. Kerr RSC, Cadoux-Hudson TA, Adams CBT. The value of accurate clinical assessment in the surgical management of the lumbar disc protrusion. J Neurol Neurosurg Psychiatry 1988 Feb;51(2):169-73.
35. Kortelainen P, Puranen J, Koivisto E, Lähde S. Symptoms and signs of sciatica and their relation to the localization of the lumbar disc herniation. Spine 1985 Jan-Feb;10(1):88-92.
36. Kosteljanetz M, Bang F, Schmidt-Olsen S. The clinical significance of straight-leg raising (Lasgue's sign) in the diagnosis of prolapsed lumbar disc. Interobserver variation and correlation with surgical finding. Spine 1988 Apr;13(4):393-5.
37. Kosteljanetz M, Espersen JO, Halaburt H, Miletic T. Predictive value of clinical and surgical findings in patients with lumbago-sciatica. A prospective study (Part I). Acta Neurochir (Wien) 1984;73(1-2):67-76.
38. Lacroix JM, Powell J, Lloyd GJ, Doxey NC, Mitson GL, Aldam CF. Low-back pain. Factors of value in predicting outcome. Spine 1990 Jun;15(6):495-9.
39. McNeill TW, Sinkora G, Leavitt F. Psychologic classification of low-back pain patients: a prognostic tool. Spine 1986 Nov;11(9):955-9.
40. Morris EW, Di Paola M, Vallance R, Waddell G. Diagnosis and decision making in lumbar disc prolapse and nerve entrapment. Spine 1986 Jun;11(5):436-9.
41. Murphy KA, Cornish RD. Prediction of chronicity in acute low back pain. Arch Phys Med Rehabil 1984 Jun;65(6):334-7.
42. Nehemkis AM, Carver DW, Evanski PM. The predictive utility of the orthopedic examination in identifying the low back pain patient with hysterical personality features. Clin Orthop 1979 Nov-Dec;(145):158-62.
43. Nykvist F, Hurme M, Alaranta H, Miettinen ML. Social factors and outcome in a five-year follow-up study of 276 patients with sciatica. Scand J Rehabil Med 1991;23(1):19-26.
44. Rae PS, Waddell G, Venner RM. A simple technique for measuring lumbar spinal flexion. Its use in orthopaedic practice. J R Coll Surg Edinb 1984 Sep;29(5):281-4.
45. Ransford AO, Cairns D, Mooney V. The pain drawing as an aid to the psychologic evaluation of patients with low-back pain. Spine 1976 Jun;1(2):127-34.
46. Roland MO, Morrell DC, Morris RW. Can general practitioners predict the outcome of episodes of back pain? Br Med J [Clin Res] 1983 Feb 12;286(6364):523-5.
47. Shiqing X, Quanzhi Z, Dehao F. Xin SQ, Zhang Qz, Fan DH. Significance of the straight-leg-raising test in the diagnosis and clinical evaluation of lower lumbar intervertebral-disc protrusion. J Bone Joint Surg 1987 Apr;69A(4):517-22.
48. Soukka A, Alaranta H, Tallroth K, Heliövaara M. Leg-length inequality in people of working age. The association between mild inequality and low-back pain is questionable. Spine 1991 Apr;16(4):429-31.
49. Spengler DM, Freeman CW. Patient selection for lumbar discectomy. An objective approach. Spine 1979 Mar-Apr;4(2):129-34.
50. Spengler DM, Ouellette EA, Battié M, Zeh J. Elective discectomy for herniation of a lumbar disc. Additional experience with an objective method. J Bone Joint Surg [Am] 1990 Feb;72(2):230-7.
51. Takata K, Inoue SI, Takahashi K, Ohtsuka Y. Swelling of the cauda equina in patients who have herniation of a lumbar disc. A possible pathogenesis of sciatica. J Bone Joint Surg [Am] 1988 Mar;70(3):361-8.
52. Udén A, Landin LA. Pain drawing and myelography in sciatic pain. Clin Orthop Rel Res 1987 Mar;216:124-30.
53. Von Baeyer CL, Bergstrom KJ, Brodwin MG, Brodwin SK. Invalid use of pain drawings in psychological screening of back pain patients. Pain 1983 May;16(1):103-7.
54. Deyo RA, Rainville J, Kent DL. What can the history and physical examination tell us about low back pain? JAMA 1992 Aug 12;268(6):760-5.
55. Waddell G, Main CJ, Morris EW, Venner RM, Rae PS, Sharmy SH, Galloway H. Normality and reliability in the clinical assessment of backache. Br Med J [Clin Res] 1982 May 22;284(6328):1519-23.
56. Aronson HA, Dunsmore RH. Herniated upper lumbar discs. J Bone Joint Surg [Am] 1963 Mar;45:311-7.
57. Bigos SJ, Battié MC, Fisher LD. Methodology for evaluating predictive factors for the report of back injury. Spine 1991 Jun;16(6):669-70.
58. Deyo RA, Diehl AK. Psychosocial predictors of disability in patients with low back pain. J Rheumatol 1988 Oct;15(10):1557-64.
59. Deyo RA, Tsui-Wu YJ. Descriptive epidemiology of low-back pain and its related medical care in the United States. Spine 1987 Apr;12(3):264-8.
60. Gran JT. An epidemiological survey of the signs and symptoms of ankylosing spondylitis. Clin Rheumatol 1985 Jun;4(2):161-9.
61. Hakelius A, Hindmarsh J. The comparative reliability of preoperative diagnostic methods in lumbar disc surgery. Acta Orthop Scand 1972;43:234-8.
62. Lowery WD, Horn TJ, Boden SD, Wiesel SW. Impairment evaluation based on spinal range of motion in normal subjects. J Spinal Disorders 1992;5(4):398-402.
63. Spangfort EV. The lumbar disc herniation. Acta Orth Scand (Suppl) 1972;142:1-95.
64. Waldvogel FA, Vasey H. Osteomyelitis: the past decade. N Engl J Med 1980 Aug14;303(7):360-70.
65. Weber H. Lumbar disc herniation. A prospective study of prognostic factors including a controlled trial. Part I. J Oslo City Hosp 1978;28:33-64.
66. Turner JA, Ersek M, Herron L, Deyo R. Surgery for lumbar spinal stenosis. Attempted meta-analysis of the literature. Spine 1992 Jan;17(1):1-8.
67. Jones SL, Jones PK, Katz J. Compliance for low-back pain patients in the emergency department. A randomized trial. Spine 1988;13(5):553-6.
68. Roland M, Dixon M. Randomized controlled trial of an educational booklet for patients presenting with back pain in general practice. J R Coll Gen Pract 1989 Jun;39(323):244-6.
69. Bass MJ, Buck C, Turner L, Dickie G, Pratt G, Robinson HC. The physician's actions and the outcome of illness in family practice. J Fam Pract 1986 Jul;23(1):43-7.
70. Deyo RA, Diehl AK. Patient satisfaction with medical care for low-back pain. Spine 1986 Jan-Feb;11(1):28-30.
71. Thomas KB. General practice consultations: is there any point in being positive? Br Med J [Clin Res] 1987 May 9;294:1200-2.
72. Bergquist-Ullman M, Larsson U. Acute low back pain in industry. A controlled prospective study with special reference to therapy and confounding factors. Acta Orthop Scand 1977;(170):1-117.
73. Berwick DM, Budman S, Feldstein M. No clinical effect of back schools in an HMO. A randomized prospective trial. Spine 1989 Mar;14(3):338-44.
74. Donchin M, Woolf O, Kaplan L, Floman Y. Secondary prevention of low-back pain. A clinical trial. Spine 1990 Dec;15(12):1317-20.
75. Evans C, Gilbert JR, Taylor W, Hildebrand A. A randomized controlled trial of flexion exercises, education, and bed rest for patients with acute low back pain. Physiotherapy Can 1987 Mar-Apr;39(2):96-101.
76. Hurri H. The Swedish back school in chronic low back pain. Part I. Benefits. Scand J Rehabil Med 1989;21(1):33-40.
77. Hurri H. The Swedish back school in chronic low back pain. Part II. Factors predicting the outcome. Scand J Rehabil Med 1989;21(1):41-4.
78. Julkunen J, Hurri H, Kankainen J. Psychological factors in the treatment of chronic low back pain. Follow-up study of a back school intervention. Psychother Psychosom 1988;50(4):173-81.
79. Keijsers JFEM, Groenman NH, Gerards FM, van Oudheusden E, Steenbakkers M. A back school in The Netherlands: evaluating the results. Patient Educ Couns 1989 Aug;14(1):31-44.
80. Keijsers JF, Steenbakkers MW, Gerards FM, Meertens RM. The efficacy of the back school: An analysis of the literature. Arthr Care Res 1990 Dec;3(4):210-15.
81. Klaber Moffett JA, Chase SM, Portek I, Ennis JR. A controlled, prospective study to evaluate the effectiveness of a back school in the relief of chronic low back pain. Spine 1986 Mar;11(2):120-2.
82. Lindequist S, Lundberg B, Wikmark R, Bergstad B, Lööf G, Ottermark AC. Information and regime at low back pain. Scand J Rehabil Med 1984;16(3):113-6.
83. Lindström I, Ohlund C, Eek C, Wallin L, Peterson L, Fordyce WE, Nachemson AL. The effect of graded activity on patients with subacute low back pain: a randomized prospective clinical study with an operant-conditioning behavioral approach. Phys Ther 1992 Apr;72(4):279-93.
84. Morrison GEC, Chase W, Young V, Roberts WL. Back pain: treatment and prevention in a community hospital. Arch Phys Med Rehabil 1988 Aug;69(8):605-9.
85. Postacchini F, Facchini M, Palieri P. Efficacy of various forms of conservative treatment in low back pain. A comparative study. Neuro-orthopedics 1988;6(1):28-35.
86. Stankovic R, Johnell O. Conservative treatment of acute low-back pain. A prospective randomized trial: McKenzie method of treatment versus patient education in mini back school [see comments]. Spine 1990 Feb;15(2):120-3.
87. Keijsers JFEM, Bouter LM, Meertens RM. Validity and comparability of studies on the effects of back schools. Physiother Theory Pract 1991;7(3):177-84.
88. Linton SJ, Kamwendo K. Low back schools. A critical review. Phys Ther 1987 Sep;67(9):1375-83.
89. Lankhorst GJ, Van de Stadt RJ, Vogelaar TW, Van der Korst JK, Prevo AJ. The effect of the Swedish Back School in chronic idiopathic low back pain. A prospective controlled study. Scand J Rehabil Med 1983;15(3):141-5.
90. Amlie E, Weber H, Holme I. Treatment of acute low-back pain with piroxicam: results of a double-blind placebo-controlled trial. Spine 1987 Jun;12(5):473-6.
91. Basmajian JV. Acute back pain and spasm. A controlled multicenter trial of combined analgesic and antispasm agents. Spine 1989 Apr;14(4):438-9.
92. Berry H, Bloom B, Hamilton EBD, Swinson DR. Naproxen sodium, diflunisal, and placebo in the treatment of chronic back pain. Ann Rheum Dis 1982;41:129-132.
93. Brooks PM, Day RO. Nonsteroidal antiinflammatory drugs-differences and similarities. N Engl J Med 1991 Jun 13;324:1716-25.
94. Cooper SA, Engel J, Ladove M, Rauch D, Precheur H, Rosenheck A. An evaluation of oxycodone and acetaminophen in the treatment of postoperative dental pain. Clin Pharmacol Ther 1979;25(2):219.
95. Fowler PD. Aspirin, paracetamol and non-steroidal anti-inflammatory drugs: A comparative review of side effects. Med Toxicol [Adverse Drug Exp] 1987;2:338-66.
96. Gall EP, Caperton EM, McComb JE, Messner R, Multz CV, O'Hanlan M, Willkens RF. Clinical comparison of ibuprofen, fenoprofen calcium, naproxen and tolmetin sodium in rheumatoid arthritis. J Rheumatol 1982;9(3):402-7.
97. Hickey RFJ. Chronic low back pain: a comparison of diflunisal with paracetamol. N Z Med J 1982;95:312-4.
98. Hopkinson JH, Bartlett FH, Steffens AO, McGlumphy TH, Macht EL, Smith M. Acetaminophen versus propoxyphene hydrochloride for relief of pain in episiotomy patients. J Clin Pharm 1973;13:251-63.
99. Jiranek GC, Kimmey MB, Saunders DR, Willson RA, Shanahan W, Silverstein FE. Misoprostol reduces gastroduodenal injury from one week of aspirin: an endoscopic study. Gastroenterology 1989;96:656-61.
100. Lanza F, Peace K, Gustitus L, Rack MF, Dickson B. A blinded endoscopic comparative study of misoprostol versus sucralfate and placebo in the prevention of aspirin-induced gastric and duodenal ulceration. Am J Gastroenterol 1988;83(2):143.
101. Scott DL, Roden S, Marshall T, Kendall MJ. Variations in responses to non-steroidal anti-inflammatory drugs. Br J Clin Pharmacol 1982;14:691-4.
102. Wallenstein SL, Houde RW. Clinical comparison of the analgesic effectiveness of N-acetyl-p-aminophenol, salicylamide and aspirin [abstract]. Fed Proc 1954;13:414.
103. Wasner C, Britton MC, Kraines G, Kye RL, Bobrove AM, Fries JF. Non-steroidal anti-inflammatory agents in rheumatoid arthritis and ankylosing spondylitis. JAMA 1981;246:2168-72.
104. Arbus L, Fajadet B, Aubert D, Morre M, Goldberger E. Activity of tetrazepam (Myolastan (R)) in low back pain. A double-blind trial v. placebo. Clin Trials J 1990;27(4):258-67.
105. Baratta RR. A double-blind study of cyclobenzaprine and placebo in the treatment of acute musculoskeletal conditions of the low back. Curr Ther Res 1982 Nov;32(5):646-52.
106. Borenstein DG, Lacks S, Wiesel SW. Cyclobenzaprine and naproxen versus naproxen alone in the treatment of acute low back pain and muscle spasm. Clin Ther 1990 Mar-Apr;12(2):125-31.
107. Boyles WF, Glassman JM, Soyka JP. Management of acute musculoskeletal conditions: thoracolumbar strain or sprain. A double-blind evaluation comparing the efficacy and safety of carisoprodol with diazepam. Today's Ther Trends 1983;1(1):1-16.
108. Casale R. Acute low back pain. Symptomatic treatment with a muscle relaxant drug. Clin J Pain 1988;4(2):81-8.
109. Dapas F, Hartman SF, Martinez L, Northrup BE, Nussdorf RT, Silberman HM, Gross H. Baclofen for the treatment of acute low-back syndrome. A double-blind comparison with placebo. Spine 1985 May;10(4):345-9.
110. Gold RH. Orphenadrine citrate: sedative or muscle relaxant? Clin Ther 1978;1(6):451-3.
111. Hindle TH 3d. Comparison of carisoprodol, butabarbital, and placebo in treatment of the low back syndrome. Calif Med 1972 Aug;117(2):7-11.
112. Hingorani K. Diazepam in backache: a double-blind controlled trial. Ann Phys Med 1965;8:303-6.
113. Klinger NM, Wilson RR, Kanniainen CM, Wagenknecht KA, Re ON, Gold RH. Intravenous orphenadrine for the treatment of lumbar paravertebral muscle strain. Curr Ther Res 1988;43(2):247-54.
114. Rollings HE, Glassman JM, Soyka JP. Management of acute musculoskeletal conditions-thoracolumbar strain or sprain: a double-blind evaluation comparing the efficacy and safety of carisoprodol with cyclobenzaprine hydrochloride. Curr Ther Res 1983 Dec;34(6):917-28.
115. Brown FL Jr, Bodison S, Dixon J, Davis W, Nowoslawski J. Comparison of diflunisal and acetaminophen with codeine in the treatment of initial or recurrent acute low back strain. Clin Ther 1986;9 Suppl C:52-8.
116. Muncie HL Jr, King DE, DeForge B. Treatment of mild to moderate pain of acute soft tissue injury: diflunisal vs acetaminophen with codeine. J Fam Pract 1986 Aug;23(2):125-7.
117. Wiesel SW, Cuckler JM, Deluca F, Jones F, Zeide MS, Rothman RH. Acute low-back pain: an objective analysis of conservative therapy. Spine 1980 Jul/Aug;5(4):324-30.
118. Heishman SJ, Stitzer ML, Bigelow GE, Liebson IA. Acute opioid physical dependence in humans: effect of varying the morphine-naloxone interval. J Pharmacol Exp Ther 1989 Aug;250(2):485-91.
119. Haimovic IC, Beresford HR. Dexamethasone is not superior to placebo for treating lumbosacral radicular pain. Neurology 1986 Dec;36(12):1593-4.
120. Felson DT, Anderson JJ. Across-study evaluation of association between steroid dose and bolus steroids and avascular neurosis of bone. Lancet 1987 Apr 18;1(8538):902-6.
121. Truhan AP, Ahmed AR. Corticosteroids: a review with emphasis on complications of prolonged systemic therapy. Ann Allergy 1989 May;62:375-90.
122. Meek JB, Giudice VW, McFadden JW, Key JD. Colchicine confirmed as highly effective in disk disorders. Final results of a double-blind study. J Neuro & Orthop Med & Surg 1985 Oct;6(3):211-8.
123. Schnebel BE, Simmons JW. The use of oral colchicine for low-back pain. A double-blind study. Spine 1988 Mar;13(3):354-7.
124. Simmons JW, Harris WP, Koulisis CW, Kimmich SJ. Intravenous colchicine for low-back pain: a double-blind study. Spine 1990 Jul;15(7):716-7.
125. Alcoff J, Jones E, Rust P, Newman R. Controlled trial of imipramine for chronic low back pain. J Fam Pract 1982 May;14(5):841-6.
126. Goodkin K, Gullion CM, Agras WS. A randomized, double-blind, placebo-controlled trial of trazodone hydrochloride in chronic low back pain syndrome. J Clin Psychopharmacol 1990 Aug;10(4):269-78.
127. Jenkins DG, Ebbutt AF, Evans CD. Tofranil in the treatment of low back pain. J Int Med Res 1976;4(28):28-40.
128. Blackwell B. Adverse effects of antidepressant drugs. Part 1: Monoamine oxidase inhibitors and tricyclics. Drugs 1981;21:201-19.
129. Blackwell B. Adverse effects of antidepressant drugs. Part 2: "Second generation" antidepressants and rational decision making in antidepressant therapy. Drugs 1981;21:272-82.
130. Brodin H. Inhibition-facilitation technique for lumbar pain treatment. Int J Rehabil Res 1984;7(3):328-9.
131. Coxhead CE, Meade TW, Inskip H, North WRS, Troup JDG. Multicentre trial of physiotherapy in the management of sciatic symptoms. Lancet 1981 May 16;8229:1065-8.
132. Farrell JP, Twomey LT. Acute low back pain. Comparison of two conservative treatment approaches. Med J Aust 1982 Feb 20;1(4):160-4.
133. Gibson T, Grahame R, Harkness J, Woo P, Blagrave P, Hills R. Controlled comparison of short-wave diathermy treatment with osteopathic treatment in non-specific low back pain. Lancet 1985 Jun 1;1(8440):1258-61.
134. Glover JR, Morris JG, Khosla T. Back pain: a randomized clinical trial of rotational manipulation of the trunk. Br J Ind Med 1974 Jan;31(1):59-64.
135. Godfrey CM, Morgan PP, Schatzker J. A randomized trial of manipulation for low-back pain in a medical setting. Spine 1984 Apr;9(3):301-4.
136. Hadler NM, Curtis P, Gillings DB, Stinnett S. A benefit of spinal manipulation as adjunctive therapy for acute low-back pain: a stratified controlled trial. Spine 1987 Sep;12(7):703-6.
137. MacDonald RS, Bell CM. An open controlled assessment of osteopathic manipulation in nonspecific low-back pain [published erratum appears in Spine 1991 Jan;16(1):104]. Spine 1990 May;15(5):364-70.
138. Mathews JA, Mills SB, Jenkins VM, Grimes SM, Morkel MJ, Mathews W, Scott CM, Sittampalam Y. Back pain and sciatica: controlled trials of manipulation, traction, sclerosant and epidural injections. Br J Rheumatol 1987 Dec;26(6):416-23.
139. Mathews W, Morkel M, Mathews J. Manipulation and traction for lumbago and sciatica: physiotherapeutic techniques used in two controlled trials. Physiother Prac 1988 Dec;4(4):201-6.
140. Waterworth RF, Hunter IA. An open study of diflunisal, conservative and manipulative therapy in the management of acute mechanical low back pain. N Z Med J 1985 May 22;98(779):372-5.
141. Anderson R, Meeker WC, Wirick BE, Mootz RD, Kirk DH, Adams A. A meta-analysis of clinical trials of spinal manipulation. J Man Physiol Ther 1992 Mar-Apr;15(3):181-94.
142. Haldeman S, Chapman-Smith D, Petersen DM, editors. Guidelines for chiropractic quality assurance and practice parameters. Proceedings of the Mercy Center Consensus Conference. 1993; Gaithersburg, MD: Aspen Publishers, Inc.;1993.
143. Jarvis KB, Phillips RB, Morris EK. Cost per case comparison of back injury claims of chiropractic versus medical management for conditions with identical diagnostic codes. J Occup Med 1991 Aug;33(8):847-52.
144. Shekelle PG, Adams AH, Chassin MR, Hurwitz EL, Brook RH. Spinal manipulation for low-back pain. Ann Intern Med 1992 Oct;117(7):590-8.
145. Coyer AB, Curwen IHM. Low back pain treated by manipulation. A controlled series. Br Med J 1955 Mar 19;1:705-7.
146. Edwards BC. Low back pain and pain resulting from lumbar spine conditions. Aust J Physiother 1969 Sep;15(3):104-10.
147. Mandell P, Lipton MH, Bernstein J, Kucera GJ, Kampner JA. Low back pain. An historical and contemporary overview of the occupational, medical, and psychosocial issues of chronic back pain. Thorofare, New Jersey: SLACK, Inc.;1989. 219 p.
148. Nwuga VCB. Relative therapeutic efficacy of vertebral manipulation and conventional treatment in back pain management. Am J Phys Med 1982 Dec;61(6):273-8.
149. Rasmussen GG. Manipulation in treatment of low-back pain (a randomized clinical trial). Man Med 1979;1:8-10.
150. Klein RG, Eek BC. Low-energy laser treatment and exercise for chronic low back pain: double-blind controlled trial. Arch Phys Med Rehabil 1990 Jan;71(1):34-7.
151. Koes BW, Bouter LM, van Mameren H, Essers AHM, Verstegen GMJR, Hofhuizen DM, Houben JP, Knipschild PG. A blinded randomized clinical trial of manual therapy and physiotherapy for chronic back and neck complaints: Physical outcome measures. J Man Physiol Ther 1992 Jan;15(1):16-23.
152. Koes BW, Bouter LM, van Mameren H, Essers AHM, Verstegen GMJR, Hofhuizen DM, Houben JP, Knipschild PG. The effectiveness of manual therapy, physiotherapy, and treatment by the general practitioner for nonspecific back and neck complaints. A randomized clinical trial. Spine 1992;17(1):28-35.
153. Koes BW, Bouter LM, van Mameren H, Essers AHM, Verstegen GM, Hofhuizen DM, Houben JP, Knipschild PG. Randomised clinical trial of manipulative therapy and physiotherapy for persistent back and neck complaints: results of one year follow up. Br Med J 1992;304:601-5.
154. Linton SJ, Bradley LA, Jensen I, Spangfort E, Sundell L. The secondary prevention of low back pain: a controlled study with follow-up. Pain 1989 Feb;36(2):197-207.
155. Manniche C, Hesselsoe G, Bentzen L, Christensen I, Lundberg E. Clinical trial of intensive muscle training for chronic low back pain. Lancet 1988 Dec 24-31;2(8626-8627):1473-6.
156. Melzack R, Vetere P, Finch L. Transcutaneous electrical nerve stimulation for low back pain. A comparison of TENS and massage for pain and range of motion. Phys Ther 1983 Apr;63(4):489-93.
157. Deyo RA, Walsh NE, Martin DC, Schoenfeld LS, Ramamurthy S. A controlled trial of transcutaneous electrical nerve stimulation (TENS) and exercise for chronic low back pain [see comments]. N Engl J Med 1990 Jun 7;322(23):1627-34.
158. Gemignani G, Olivieri I, Ruju G, Pasero G. Transcutaneous electrical nerve stimulation in ankylosing spondylitis: a double-blind study [letter]. Arthritis Rheum 1991 Jun;34(6):788-9.
159. Graff-Radford SB, Reeves JL, Baker RL, Chiu D. Effects of transcutaneous electrical nerve stimulation on myofascial pain and trigger point sensitivity. Pain 1989;37:1-5.
160. Hackett GI, Seddon D, Kaminski D. Electroacupuncture compared with paracetamol for acute low back pain. Practitioner 1988 Feb 22;232(1443):163-4.
161. Lehmann TR, Russell DW, Spratt KF. The impact of patients with nonorganic physical findings on a controlled trial of transcutaneous electrical nerve stimulation and electroacupuncture. Spine 1983 Sep;8(6):625-34.
162. Lehmann TR, Russell DW, Spratt KF, Colby H, Liu YK, Fairchild ML, Christensen S. Efficacy of electroacupuncture and TENS in the rehabilitation of chronic low back pain patients. Pain 1986 Sep;26(3):277-90.
163. Thorsteinsson G, Stonnington HH, Stillwell GK, Elveback LR. Transcutaneous electrical stimulation: a double-blind trial of its efficacy for pain. Arch Phys Med Rehabil 1977 Jan;58:8-13.
164. Thorsteinsson G, Stonnington HH, Stillwell GK, Elveback LR. The placebo effect of transcutaneous electrical stimulation. Pain 1978;5:31-41.
165. Basford JR, Smith MA. Shoe insoles in the workplace. Orthopedics 1988 Feb;11(2):285-8.
166. Battié MC, Bigos SJ, Fisher LD, Spengler DM, Hansson TH, Nachemson AL, Wortley MD. The role of spinal flexibility in back pain complaints within industry. A prospective study. Spine 1990 Aug;15(8):768-73.
167. Horal J. The clinical appearance of low back disorders in the city of Gothenburg, Sweden. Comparisons of incapacitated probands with matched controls. Acta Orthop Scand Suppl 1969;118:15-23,68-73.
168. Hult L. Cervical, dorsal and lumbar spinal syndromes. Acta Orthop Scand Suppl 1954;16:7-73.
169. Reddell CR, Congleton JJ, Huchingson RD, Montgomery JF. An evaluation of a weightlifting belt and back injury prevention training class for airline baggage handlers. Applied Ergonomics 1992;23(5):319-29.
170. Walsh NE, Schwartz RK. The influence of prophylactic orthoses on abdominal strength and low back injury in the workplace [see comments]. Am J Phys Med Rehabil 1990 Oct;69(5):245-50.
171. Million R, Haavik Nilsen K, Jayson MIV, Baker RD. Evaluation of low back pain and assessment of lumbar corsets with and without back supports. Ann Rheum Dis 1981;40:449-54.
172. Larsson U, Chöler U, Lidström A, Lind G, Nachemson A, Nilsson B, Roslund J. Auto-traction for treatment of lumbago-sciatica. A multicentre controlled investigation. Acta Orthop Scand 1980 Oct;51(5):791-8.
173. Mathews JA, Hickling J. Lumbar traction: a double-blind controlled study for sciatica. Rheumatol Rehabil 1975;14:222-5.
174. Pal B, Mangion P, Hossain MA, Diffey BL. A controlled trial of continuous lumbar traction in the treatment of back pain and sciatica. Br J Rheumatol 1986 May;25(2):181-3.
175. Weber H, Ljunggren AE, Walker L. Traction therapy in patients with herniated lumbar intervertebral discs. J Oslo City Hosp 1984 Jul-Aug;34(7-8):61-70.
176. Haskvitz EM, Hanten WP. Blood pressure response to inversion traction. Phys Ther 1986 Sep;66(9):1361-4.
177. Asfour SS, Khalil TM, Waly SM, Goldberg ML, Rosomoff RS, Rosomoff HL. Biofeedback in back muscle strengthening. Spine 1990 Jun;15(6):510-3.
178. Bush C, Ditto B, Feuerstein M. A controlled evaluation of paraspinal EMG biofeedback in the treatment of chronic low back pain. Health Psychol 1985;4(4):307-21.
179. Flor H, Haag G, Turk DC, Koehler H. Efficacy of EMG biofeedback, pseudotherapy, and conventional medical treatment for chronic rheumatic back pain. Pain 1983 Sep;17(1):21-31.
180. Nouwen A. EMG biofeedback used to reduce standing levels of paraspinal muscle tension in chronic low back pain. Pain 1983 Dec;17(4):353-60.
181. Flor H, Haag G, Turk DC. Long-term efficacy of EMG biofeedback for chronic rheumatic back pain. Pain 1986 Nov;27(2):195-202.
182. Stuckey SJ, Jacobs A, Goldfarb J. EMG biofeedback training, relaxation training, and placebo for the relief of chronic back pain. Percept Mot Skills 1986 Dec;63(3):1023-36.
183. Bourne IH. Treatment of chronic back pain. Comparing corticosteroid-lignocaine injections with lignocaine alone. Practitioner 1984 Mar;228(1389):333-8.
184. Frost FA, Jessen B, Siggaard-Andersen J. A control, double-blind comparison of mepivacaine injection versus saline injection for myofascial pain. Lancet 1980 Mar 8;8167:499-501.
185. Garvey TA, Marks MR, Wiesel SW. A prospective, randomized, double-blind evaluation of trigger-point injection therapy for low-back pain. Spine 1989 Sep;14(9):962-4.
186. Collée G, Dijkmans BAC, Vandenbroucke JP, Cats A. Iliac crest pain syndrome in low back pain. A double blind, randomized study of local injection therapy. J Rheumatol 1991;18(7):1060-3.
187. Ongley MJ, Klein RG, Dorman TA, Eek BC, Hubert LJ. A new approach to the treatment of chronic low back pain. Lancet 1987 Jul 18;2(8551):143-6.
188. Sonne M, Christensen K, Hansen SE, Jensen EM. Injection of steroids and local anaesthetics as therapy for low-back pain. Scand J Rheumatol 1985;14(4):343-5.
189. Sullivan JGB. The anesthesiologist's approach to back pain. In: Herkowitz HN, Garfin SR, Balderston RA, Eismont FJ, Bell GR, Wiesel SW, editors. The Spine 3rd ed. Philadelphia: W.B. Saunders Co.;1992. p. 1945-61.
190. Wilkinson HA. Alternative therapies for the failed back syndrome. In: Frymoyer JW, editor. The adult spine: principles and practice. New York: Raven Press, Ltd.;1991:2069-91.
191. Jackson RP. The facet syndrome. Myth or reality? Clin Orthop Rel Res 1992 Jun;279:110-21.
192. Carette S, Marcoux S, Truchon R, Grondin C, Gagnon J, Allard Y, Latulippe M. A controlled trial of corticosteroid injections into facet joints for chronic low back pain. N Engl J Med 1991 Oct 3;325(14):1002-7.
193. Lilius G, Laasonen EM, Myllynen P, Harilainen A, Grönlund G. Lumbar facet joint syndrome. A randomised clinical trial. J Bone Joint Surg [Br] 1989 Aug;71(4):681-4.
194. Marks RC, Houston T, Thulbourne T. Facet joint injection and facet nerve block: a randomised comparison in 86 patients with chronic low back pain. Pain 1992;49:325-8.
195. Nash TP. Facet joints-intra-articular steroids or nerve block? Pain Clinic 1990; 3(2):77-82.
196. Thomson SJ, Lomax DM, Collett BJ. Chemical meningism after lumbar facet joint block with local anaesthetic and steroids. Anaesthesia 1991 Jul;46(7):563-4.
197. Warfield CA. Facet syndrome and the relief of low back pain. Hosp Pract [Off] 1988 Oct 30;23(10A):41-2,47-8.
198. Mooney V. Injection studies. Role in pain definition. In: Frymoyer JW, editor. The adult spine: principles and practice. New York: Raven Press, Ltd.; 1991. p. 527-40.
199. White AH. Injection techniques for the diagnosis and treatment of low back pain. Orthop Clin North Am 1983 Jul;14(3):553-67.
200. Breivik H, Hesla PE, Molnar I, Lind B. Treatment of chronic low back pain and sciatica: Comparison of caudal epidural injections of bupivacaine and methylprednisolone with bupivacaine followed by saline. Adv Pain Res Ther 1976;1:927-32.
201. Bush K, Hillier S. A controlled study of caudal epidural injections of triamcinolone plus procaine for the management of intractable sciatica. Spine 1991;16(5):572-5.
202. Cuckler JM, Bernini PA, Wiesel SW, Booth RE Jr, Rothman RH, Pickens GT. The use of epidural steroids in the treatment of lumbar radicular pain. A prospective, randomized, double-blind study. J Bone Joint Surg [Am] 1985 Jan;67(1):63-6.
203. Dallas TL, Lin RL, Wu WH, Wolskee P. Epidural morphine and methylprednisolone for low-back pain. Anesthesiology 1987 Sep;67(3):408-11.
204. Dilke TF, Burry HC, Grahame R. Extradural corticosteroid injection in management of lumbar nerve root compression. Br Med J 1973 Jun 16;2(867):635-7.
205. Klenerman L, Greenwood R, Davenport HT, White DC, Peskett S. Lumbar epidural injections in the treatment of sciatica. Br J Rheumatol 1984;23(1):35-8.
206. Ridley MG, Kingsley GH, Gibson T, Grahame R. Outpatient lumbar epidural corticosteroid injection in the management of sciatica. Br J Rheumatol 1988;27(4):295-9.
207. Snoek W, Weber H, Jorgensen B. Double blind evaluation of extradural methyl prednisolone for herniated lumbar discs. Acta Orthop Scand 1977;48:635-41.
208. Kepes ER, Duncalf D. Treatment of backache with spinal injections of loca anesthetics, spinal and systemic steroids. A review. Pain 1985 May;22(1):33-47.
209. Rocco AG, Frank E, Kaul AF, Lipson SJ, Gallo JP. Epidural steroids, epidural morphine and epidural steroids combined with morphine in the treatment of post-laminectomy syndrome. Pain 1989 Mar;36(3):297-303.
210. Coan RM, Wong G, Ku SL, Chan YC, Wang L, Ozer FT, Coan PL. The acupuncture treatment of low back pain: a randomized controlled trial. Am J Chin Med 1980;8(2):181-9.
211. Edelist G, Gross AE, Langer F. Treatment of low back pain with acupuncture. Can Anaesth Soc J 1976 May;23(3):303-6.
212. Ghia JN, Mao W, Toomey TC, Gregg JM. Acupuncture and chronic pain mechanisms. Pain 1976;2:285-99.
213. Gunn CC, Milbrandt WE. Tenderness at motor points. A diagnostic and prognostic aid for low-back injury. J Bone Joint Surg [Am] 1976 Sep;58(6):815-25.
214. Mendelson G, Kidson MA, Loh ST, Scott DF, Selwood TS, Kranz H. Acupuncture analgesia for chronic low back pain. Clin Exp Neurol 1978;15:182-5.
215. Mendelson G, Selwood TS, Kranz H, Loh TS, Kidson MA, Scott DS. Acupuncture treatment of chronic back pain. A double-blind placebo-controlled trial. Am J Med 1983 Jan;74(1):49-55.
216. ter Riet G, Kleijnen J, Knipschild P. Acupuncture and chronic pain: a criteria-based meta-analysis. J Clin Epidemiol 1990;43(11):1191-9.
217. Kent G, Brondum J, Keenlyside RA, Lafazia LM, Scott HD. A large outbreak of acupuncture-associated hepatitis B. Am J Epidemiol 1988;127(3):591-8.
218. Lee MHM, Liao S, Kottke FJ, Lehmann JF. Krusen's handbook of physical medicine and rehabilitation. Philadelphia: Saunders; 1990. Chapter 16, Acupuncture in physiatry.
219. Willms D. Possible complications of acupuncture [letter]. The West J Med 1991;154(6):736-7.
220. Wright R, Kupperman JL, Liebhaber MI. Bilateral tension pneumothoraces after acupuncture. West J Med 1991:154(1);102-3.
221. Chaffin DB. A biomechanical strength model for use in industry. Appl Ind Hyg 1988 Mar;3(3):79-86.
222. Damkot DK, Pope MH, Lord J, Frymoyer JW. The relationship between work history, work environment and low back pain in men. Spine 1984;9:395-9.
223. Drury CG. Influence of restricted space on manual materials handling. Ergonomics 1985 Jan;28(1):167-75.
224. Dul J, Hilderbrandt VH. Ergonomic guidelines for the prevention of low back pain at the workplace. Ergonomics 1987 Feb;30(2):419-29.
225. Garg A, Moore JS. Epidemiology of low-back pain in industry. Occup Med 1992 Oct-Dec;7(4):593-608.
226. Nachemson AL. Disc pressure measurements. Spine 1981 Jan/Feb;6(1):93-7.
227. National Institute for Occupational Safety and Health (NIOSH). Work practices guide for manual lifting. US Department of Health and Human Services, National Institute for Occupational Safety and Health, Cincinnati, OH: March 1981, NIOSH Technical Report No. 81-122.
228. Waters TR, Putz-Anderson V, Garg A, Fine LJ. Revised NIOSH equation for the design and evaluation of manual lifting tasks. Ergonomics 1993;36(7):749-76.
229. Deyo RA, Diehl AK, Rosenthal M. How many days of bed rest for acute low back pain? A randomized clinical trial. N Engl J Med 1986 Oct 23;315(17):1064-70.
230. Gilbert JR, Taylor DW, Hildebrand A, Evans C. Clinical trial of common treatments for low back pain in family practice. Br Med J [Clin Res] 1985 Sep 21;291(6498):791-4.
231. Bortz WM. The disuse syndrome. West J Med 1984 Nov;141(5):691-4.
232. Deyo RA. Non-operative treatment of low back disorders. Differentiating useful from useless therapy. In: Frymoyer JW, editor. The adult spine: principles and practice. New York: Raven Press, Ltd.;1991. p. 1567-80.
233. Buswell J. Low back pain: a comparison of two treatment programmes. N Z J Physiother 1982 Aug;10(2):13-7.
234. Davies JE, Gibson T, Tester L. The value of exercises in the treatment of low back pain. Rheumatol Rehabil 1979;18:243-7.
235. Donelson R, Grant W, Kamps C, Medcalf R. Pain response to sagittal end-range spinal motion. A prospective, randomized, multicentered trial. Spine 1991 Jun;16(6 Suppl):S206-12.
236. Gundewall B, Liljeqvist M, Hansson T. Primary prevention of back symptoms and absence from work. A prospective randomized study among hospital employees. Spine 1993;18(5):587-94.
237. Kellett KM, Kellett DA, Nordholm LA. Effects of an exercise program on sick leave due to back pain. Phys Ther 1991 Apr;71(4):283-91; discussion 291-3.
238. Kendall PH, Jenkins JM. Exercises for backache: a double-blind controlled trial. Physiotherapy 1968;54:154-7.
239. Lidström A, Zachrisson M. Physical therapy on low back pain and sciatica. An attempt at evaluation. Scand J Rehab Med 1970;2:37-42.
240. McCain GA, Bell DA, Mai FM, Halliday PD. A controlled study of the effects of a supervised cardiovascular fitness training program on the manifestations of primary fibromyalgia. Arthritis Rheum 1988 Sep;31(9):1135-41.
241. Reilly K, Lovejoy B, Williams R, Roth H. Differences between a supervised and independent strength and conditioning program with chronic low back syndromes. J Occup Med 1989 Jun;31(6):547-50.
242. Turner JA, Clancy S, McQuade KJ, Cardenas DD. Effectiveness of behavioral therapy for chronic low back pain: a component analysis. J Consult Clin Psychol 1990 Oct;58(5):573-9.
243. Zylbergold RS, Piper MC. Lumbar disc disease: comparative analysis of physical therapy treatments. Arch Phys Med Rehabil 1981 Apr;62:176-9.
244. Andersson GBJ. Posture and compressive spine loading: intradiscal pressures, trunk myoelectric activities, intra-abdominal pressures, and biochemical analyses. Ergonomics 1985;28(1):91-3.
245. Andersson GBJ, Örtengren R, Nachemson AL, Elstrm G, Broman H. The sitting posture: an electromyographic and discometric study. Orthop Clin North Am 1975 Jan;6(1):105-20.
246. Fordyce WE, Brockway JA, Bergman JA, Spengler D. Acute back pain: a control-group comparison of behavioral vs traditional management methods. J Behav Med 1986 Apr;9(2):127-40.
247. Nachemson A. Towards a better understanding of low-back pain: a review of the mechanics of the lumbar disc. Rheumatol Rehabil 1975;14:129-43.
248. Nachemson AL. The lumbar spine. An orthopaedic challenge. Spine 1976 Mar;1(1):59-71.
249. Nachemson A, Elfström G. Intravital dynamic pressure measurements in lumbar discs. A study of common movements, maneuvers and exercises. Scand J Rehabil Med Suppl 1970;1:1-40.
250. Nordin M, Örtengren R, Andersson GBJ. Measurements of trunk movements during work. Spine 1984;9(5):465-9.
251. Sachs BL, Ahmad SS, LaCroix M, Olimpio D, Heath R, David JA, Scala AD. Objective assessment for exercise treatment on the B-200 isostation as part of work tolerance rehabilitation. A random prospective blind evaluation with comparison control population. Spine 1994 Jan 1;19(1):49-52.
252. Schultz AB, Andersson GBJ. Analysis of loads on the lumbar spine. Spine 1981 Jan-Feb;6(1):76-82.
253. Schultz AB, Andersson GBJ, Örtengren R, Haderspeck K, Nachemson A. Loads on the lumbar spine. Validation of a biomechanical analysis by measurements of intradiscal pressures and myoelectric signals. J Bone Joint Surg [Am] 1982;64:713-20.
254. Aiello I, Serra G, Tugnoli V, Cristofori MC, Migliore A, Roccella P, Rosati G. Electrophysiological findings in patients with lumbar disc prolapse. Electromyogr Clin Neurophysiol 1984 May;24(4):313-20.
255. Arena JG, Sherman RA, Bruno GM, Young TR. Electromyographic recordings of low back pain subjects and non-pain controls in six different positions: effect of pain levels. Pain 1991 Apr;45(1):23-8.
256. Braddom RI, Johnson EW. Standardization of H reflex and diagnostic use in S1 radiculopathy. Arch Phys Med Rehabil 1974 Apr;55:161-6.
257. Khatri BO, Baruah J, McQuillen MP. Correlation of electromyography with computed tomography in evaluation of lower back pain. Arch Neurol 1984 Jun;41(6):594-7.
258. Sihvonen T, Partanen J, Hänninen O, Soimakallio S. Electric behavior of low back muscles during lumbar pelvic rhythm in low back pain patients and healthy controls. Arch Phys Med Rehabil 1991 Dec;72:1080-7.
259. Stolov WC, Slimp JC. Dermatomal somatosensory evoked potentials in lumbar spinal stenosis. Am Assoc Electromyography and Electrodiagnosis, Am Electroencephalography Soc Joint Symp 1988:17-22.
260. Young A, Getty J, Jackson A, Kirwan E, Sullivan M, Parry CW. Variations in the pattern of muscle innervation by the L5 and S1 nerve roots. Spine 1983 Sep;8(6):616-24.
261. Ahern DK, Follick MJ, Council JR, Laser-Wolston N, Litchman H. Comparison of lumbar paravertebral EMG patterns in chronic low back pain patients and non-patient controls. Pain 1988 Aug;34(2):153-60.
262. Esdaile JM, Rosenthall L, Terkeltaub R, Kloiber R. Prospective evaluation of sacroiliac scintigraphy in chronic inflammatory back pain. Arthritis Rheum 1980 Sep;23(9):998-1003.
263. Lowe J, Schachner E, Hirschberg E, Shapiro Y, Libson E. Significance of bone scintigraphy in symptomatic spondylolysis. Spine 1984 Sep;9(6):653-5.
264. Miron SD, Khan MA, Wiesen EJ, Kushner I, Bellon EM. The value of quantitative sacroiliac scintigraphy in detection of sacroiliitis. Clin Rheumatol 1983 Dec;2(4):407-14.
265. Schütte HE, Park WM. The diagnostic value of bone scintigraphy in patients with low back pain. Skeletal Radiol 1983;10(1):1-4.
266. Whalen JL, Brown ML, McLeod R, Fitzgerald RH Jr. Limitations of indium leukocyte imaging for the diagnosis of spine infections. Spine 1991 Feb;16(2):193-7.
267. Mills GH, Davies GK, Getty CJM, Conway J. The evaluation of liquid crystal thermography in the investigation of nerve root compression due to lumbosacral lateral spinal stenosis. Spine 1986 Jun;11(5):427-32.
268. Hoffman RM, Kent DL, Deyo RA. Diagnostic accuracy and clinical utility of thermography for lumbar radiculopathy. A meta-analysis. Spine 1991 Jun;16(6):623-8.
269. Chafetz N, Wexler CE, Kaiser JA. Neuromuscular thermography of the lumbar spine with CT correlation. Spine 1988 Aug;13(8):922-5.
270. Harper CM Jr, Low PA, Fealey RD, Chelimsky TC, Proper CJ, Gillen DA. Utility of thermography in the diagnosis of lumbosacral radiculopathy. Neurology 1991 Jul;41(7):1010-4.
271. Perelman RB, Adler D, Humphreys M. Electronic infrared thermography. A clinical comparison with computerized tomography of the lumbosacral spine. J Neurol Orthop Med Surg 1985 Apr;6(1):7-12.
272. So YT, Aminoff MJ, Olney RK. The role of thermography in the evaluation of lumbosacral radiculopathy [see comments]. Neurology 1989 Sep;39(9):1154-8.
273. Boden SD, Davis DO, Dina TS, Patronas NJ, Wiesel SW. Abnormal magnetic-resonance scans of the lumbar spine in asymptomatic subjects. J Bone Joint Surg [Am] 1990;72(3):403-8.
274. Hitselberger WE, Witten RM. Abnormal myelograms in asymptomatic patients. J Neurosurg 1968;28:204-6.
275. Wiesel SW, Tsourmas N, Feffer HL, Citrin CM, Patronas N. A study of computer-assisted tomography. I. The incidence of positive CAT scans in an asymptomatic group of patients. Spine 1984 Sep;9(6):549-51.
276. Biering-Sorensen F, Hansen FR, Schroll M, Runeborg O. The relation of spinal x-ray to low-back pain and physical activity among 60-year-old men and women. Spine 1985 Jun;10(5):445-51.
277. Bigos SJ, Hansson T, Castillo RN, Beecher PJ, Wortley MD. The value of preemployment roentgenographs for predicting acute back injury claims and chronic back pain disability. Clin Orthop Rel Res 1992 Oct;283:124-9.
278. Deyo RA, Diehl AK. Lumbar spine films in primary care: current use and effects of selective ordering criteria. J Gen Intern Med 1986 Jan-Feb;1(1):20-5.
279. Fullenlove TM, Williams AJ. Comparative roentgen findings in symptomatic and asymptomatic backs. Radiology 1957;68:572-4.
280. Grubb SA, Lipscomb HJ, Guilford WB. The relative value of lumbar roentgenograms, metrizamide myelography, and discography in the assessment of patients with chronic low-back syndrome. Spine 1987 Apr;12(3):282-6.
281. Hansson T, Bigos S, Beecher P, Wortley M. The lumbar lordosis in acute and chronic low-back pain. Spine 1985 Mar;10(2):154-5.
282. Kaplan DM, Knapp M, Romm FJ, Velez R. Low back pain and x-ray films of the lumbar spine: a prospective study in primary care. South Med J 1986 Jul;79(7):811-4.
283. LaRocca H, Macnab I. Value of pre-employment radiographic assessment of the lumbar spine. Can Med Assoc J 1969 Oct 4;101:49-54.
284. LaRocca H, Macnab I.Indus Med
285. Leboeuf C, Kimber D, White K. Prevalence of spondylolisthesis, transitional anomalies and low intercrestal line in a chiropractic patient population. J Manipulative Physiol Ther 1989 Jun;12(3):200-4.
286. Libson E, Bloom RA, Dinari G. Symptomatic and asymptomatic spondylolysis and spondylisthesis in young adults. Int Orthop 1982;6:259-61.
287. Libson E, Bloom RA, Dinari G, Robin GC. Oblique lumbar spine radiographs: importance in young patients. Radiology 1984 Apr;151(1):89-90.
288. Magora A, Schwartz A. Relation between the low back pain syndrome and x-ray findings. 1. Degenerative osteoarthritis. Scand J Rehab Med 1976;8:115-25.
289. Magora A, Schwartz A. Relation between the low back pain syndrome and x-ray findings. 3. Spina bifida occulta. Scand J Rehabil Med 1980;12(1):9-15.
290. Magora A, Schwartz A. Relation between low back pain and x-ray changes. 4. Lysis and olisthesis. Scand J Rehabil Med 1980;12(2):47-52.
291. Paajanen H, Erkintalo M, Dahlström S, Kuusela T, Svedstrm E, Kormano M. Disc degeneration and lumbar instability. Magnetic resonance examination of 16 patients. Acta Orthop Scand 1989 Aug;60(4):375-8.
292. Splithoff CA. Lumbosacral junction: roentgenographic comparison of patients with and without backaches. JAMA 1953 Aug 22;152(17):1610-3.
293. Swärd L, Hellström M, Jacobsson B, Peterson L. Back pain and radiologic changes in the thoraco-lumbar spine of athletes. Spine 1990 Feb;15(2):124-9.
294. Torgerson WR, Dotter WE. Comparative roentgenographic study of the asymptomatic and symptomatic lumbar spine. J Bone Joint Surg 1976 Sep;58(6):850-3.
295. Boxall D, Bradford DS, Winter RB, Moe JH. Management of severe spondylolisthesis in children and adolescents. J Bone Joint Surg [Am] 1979 June;61-A(4):479-495.
296. Hall FM. Back pain and the radiologist. Radiology 1980 Dec;137(3):861-3.
297. Kent DL, Haynor DR, Larson EB, Deyo RA. Diagnosis of lumbar spinal stenosis in adults: A metaanalysis of the accuracy of CT, MR, and myelography. Am J Roentgenol 1992 May;158:1135-44.
298. Fries JW, Abodeely DA, Vijungco JG, Yeager VL, Gaffey WR. Computed tomography of herniated and extruded nucleus pulposus. J Comput Assist Tomogr 1982 Oct;6(5):874-87.
299. Gillström P, Ericsson K, Hindmarsh T. A comparison of computed tomography and myelography in the diagnosis of lumbar disc herniation. Arch Orthop Trauma Surg 1986;106(1):12-4.
300. Haughton VM, Eldevik OP, Magnaes B, Amundsen P. A prospective comparison of computed tomography and myelography in the diagnosis of herniated lumbar disks. Neuroradiology 1982 Jan;142(1):103-10.
301. Hirsch C, Nachemson A. The reliability of lumbar disk surgery. Clin Orthop 1963;29:189.
302. Jackson RP, Cain JE, Becker GJ, Jacobs RR, [Montesano PX,] Cooper BR, McManus GE. The neuroradiographic diagnosis of lumbar herniated nucleus pulposus: I. A comparison of computed tomography(CT), myelography, CT-myelography, discography, and CT-discography. Spine 1989;14(12):1356-60.
303. Jackson RP, Cain JE, Jacobs RR, Cooper BR, McManus GE. The neuroradiographic diagnosis of lumbar herniated nucleus pulposus: II. A comparison of computed tomography(CT), myelography, CT-myelography, and magnetic resonance imaging. Spine 1989;14(12):1362-7.
304. Ketonen L, Gyldensted C. Lumbar disc disease evaluated by myelography and postmyelography spinal computed tomography. Neuroradiology 1986;28(2):144-9.
305. Masaryk TJ, Ross JS, Modic MT, Boumphrey F, Bohlman H, Wilber G. High-resolution MR imaging of sequestered lumbar intervertebral disks. Am J Roentgenol 1988 May;150:1155-62.
306. Modic MT, Masaryk T, Boumphrey F, Goormastic M, Bell G. Lumbar herniated disk disease and canal stenosis: prospective evaluation by surface coil MR, CT, and myelography. AJR 1986 Oct;147(4):757-65.
307. Moufarrij NA, Hardy RW, Weinstein MA. Computed tomographic, myelographic, and operative findings in patients with suspected herniated lumbar discs. Neurosurgery 1983 Feb;12(2):184-8.
308. Schipper J, Kardaun JW, Braakman R, van Dongen KJ, Blaauw G. Lumbar disk herniation: diagnosis with CT or myelography. Radiology 1987 Oct;165(1):227-31.
309. Slebus FG, Braakman R, Schipper J, van Dongen KJ, Westendorp-de Serire M. Non-corresponding radiological and surgical diagnoses in patients operated for sciatica. Acta Neurochir 1988;94:137-43.
310. Szypryt EP, Twining P, Wilde GP, Mulholland RC, Worthington BS. Diagnosis of lumbar disc protrusion. A comparison between magnetic resonance imaging and radiculography. J Bone Joint Surg [Br] 1988 Nov;70(5):717-22.
311. Sackett DL, Haynes RB, Guyatt GH, Tugwell P. Clinical epidemiology: a basic science for clinical medicine. 2nd ed. Boston/Toronto/London: Little, Brown and Co.; 1991. 441 p.
312. Bell GR, Rothman RH, Booth RE, Cuckler JM, Garfin S, Herkowitz H, Simeone FA, Dolinskas C, Han SS. A study of computer-assisted tomography. II. Comparison of metrizamide myelography and computed tomography in the diagnosis of herniated lumbar disc and spinal stenosis. Spine 1984;9(6):552-6.
313. Bolender NF, Schönström NSR, Spengler DM. Role of computed tomography and myelography in the diagnosis of central spinal stenosis. J Bone Joint Surg 1985 Feb;67A(2):240-6.
314. Epstein NE, Epstein JA, Carras R, Hyman RA. Far lateral lumbar disc herniations and associated structural abnormalities. An evaluation in 60 patients of the comparative value of CT, MRI, and myelo-CT in diagnosis and management. Spine 1990 Jun;15(6):534-9.
315. Herkowitz HN, Gafin SR, Bell GR, Bumphrey F, Rothman RH. The use of computerized tomography in evaluating non-visualized vertebral levels caudad to a complete block on a lumbar myelogram. J Bone Joint Surg 1987 Feb;69A(2):218-24.
316. Modic MT, Pavlicek W, Weinstein MA, Boumphrey F, Ngo F, Hardy R, Duchesneau PM. Magnetic resonance imaging of intervertebral disk disease. Radiology 1984 Jul;152(1):103-11.
317. Schnebel B, Kingston S, Watkins R, Dillin W. Comparison of MRI to contrast CT in the diagnosis of spinal stenosis. Spine 1989 Mar;14(3):332-7.
318. Schönström NSR, Bolender NF, Spengler DM. The pathomorphology of spinal stenosis as seen on CT scans of the lumbar spine. Spine 1985;10(9):806-11.
319. Stockley I, Getty CJM, Dixon AK, Glaves I, Euinton HA, Barrington NA. Lumbar lateral canal entrapment: clinical, radiculographic and computed tomographic findings. Clin Radiol 1988;39:144-9.
320. Voelker JL, Mealey J Jr, Eskridge JM, Gilmor RL. Metrizamide-enhanced computed tomography as an adjunct to metrizamide myelography in the evaluation of lumbar disc herniation and spondylosis. Neurosurgery 1987 Mar;20(3):379-84.
321. Zlatkin MB, Lander PH, Hadjipavlou AG, Levine JS. Paget disease of the spine: CT with clinical correlation. Radiology 1986 Jul;160(1):155-9.
322. Powell MC, Wilson M, Szypryt P, Symonds EM, Worthington BS. Prevalence of lumbar disc degeneration observed by magnetic resonance in symptomless women. Lancet 1986 Dec 13;2(8520):1366-7.
323. Weinreb JC, Wolbarsht LB, Cohen JM, Brown CE, Maravilla KR. Prevalence of lumbosacral intervertebral disk abnormalities on MR images in pregnant and asymptomatic nonpregnant women. Radiology 1989 Jan;170(1 Pt 1):125-8.
324. Colhoun E, McCall IW, Williams L, Cassar Pullicino VN. Provocationy discography as a guide to planning operations on the spine. J Bone Joint Surg [Br] 1988 Mar;70(2):267-71.
325. Gill K, Jackson RP. CT-Discography. In: Frymoyer JW, editor. The adult spine: principles and practice. New York: Raven Press, Ltd.;1991. p. 443-56.
326. Holt EP. The question of lumbar discography. J Bone Joint Surg [Am] 1968 Jun;50(4):720-6.
327. Walsh TR, Weinstein JN, Spratt KF, Lehmann TR, Aprill C, Sayre H. Lumbar discography in normal subjects. A controlled, prospective study. J Bone Joint Surg [Am] 1990 Aug;72(7):1081-8.
328. Crawshaw C, Frazer AM, Merriam WF, Mulholland RC, Webb JK. A comparison of surgery and chemonucleolysis in the treatment of sciatica. A prospective randomized trial. Spine 1984 Mar;9(2):195-8.
329. Ejeskär A, Nachemson A, Herberts P, Lysell E, Andersson G, Irstam L, Peterson LE. Surgery versus chemonucleolysis for herniated lumbar discs. A prospective study with random assignment. Clin Orthop 1983 Apr;(174):236-42.
330. Fraser RD. Chymopapain for the treatment of intervertebral disc herniation: A preliminary report of a double-blind study. Spine 1982;7:608-12.
331. Fraser RD. Chymopapain for the treatment of intervertebral disc herniation. The final report of a double-blind study. Spine 1984 Nov-Dec;9(8):815-8.
332. Gogan WJ, Fraser RD. Chymopapain. A 10-year, double-blind study. Spine 1992;17(4):388-94.
333. Javid MJ, Nordby EJ, Ford LT, Hejna WJ, Whisler WW, Burton C, Millett DK, Wiltse LL, Widell EH Jr, Boyd RJ, Newton SE, Thisted R. Safety and efficacy of chymopapain (Chymodiactin) in herniated nucleus pulposus with sciatica. Results of a randomized, double-blind study. JAMA 1983 May 13;249(18):2489-94.
334. Revel M, Payan C, Vallee C, Laredo JD, Lassale B, Roux C, Carter H, Salomon C, Delmas E, Roucoules J, Beauvais C, Savy JM, Chicheportiche V, Bourgeois P, Smadja M, Hercot O, Wybier M, Cagan G, Blum-Boisgard C, Fermanian J. Automated percutaneous lumbar discectomy versus chemonucleolysis in the treatment of sciatica. Spine 1993;18(1):1-7.
335. Tullberg T, Isacson J, Weidenhielm L. Does microscopic removal of lumbar disc herniation lead to better results than the standardized procedure? Results of a one-year randomized study. Spine 1993;18(1):17-20.
336. van Alphen HAM, Braakman R, Bezemer PD, Broere G, Berfelo MW. Chemonucleolysis versus discectomy: a randomized multicenter trial. J Neurosurg 1989 Jun;70(6):869-75.
337. Watters WC 3d, Mirkovic S, Boss J. Treatment of the isolated lumbar intervertebral disc herniation: microdiscectomy versus chemonucleolysis. Spine 1988 Mar;13(3):360-2.
338. Weber H. The effect of delayed disc surgery on muscular paresis. Acta Orthop Scand 1975;46:631-42.
339. Weber H. Lumbar disc herniation. A controlled, prospective study with ten years of observation. Spine 1983 Mar;8(2):131-40.
340. Hoffman RM, Wheeler KJ, Deyo RA. Surgery for herniated lumbar discs: A literature synthesis. J Gen Intern Med 1993 Sept;8:487-96.
341. Agre K, Wilson RR, Brim M, McDermott DJ. Chymodiactin postmarketing surveillance. Demographic and adverse experience data in 29,075 patients. Spine 1984 Jul-Aug;9(5):479-85.
342. Alexander AH, Burkus JK, Mitchell JB, Ayers WV. Chymopapain chemonucleolysis versus surgical discectomy in a military population. Clin Orthop 1989 Jul;(244):158-65.
343. Bouillet R. Treatment of sciatica. A comparative survey of complications of surgical treatment and nucleolysis with chymopapain. Clin Orthop 1990 Feb;(251):144-52.
344. Deeb ZL, Schimel S, Daffner RH, Lupetin AR, Hryshko FG, Blakley JB. Intervertebral disk-space infection after chymopapain injection. Am J Neuroradiol 1985;6(1):55-58.
345. Deyo RA, Cherkin DC, Loeser JD, Bigos SJ, Ciol M. Morbidity and mortality in association with operations on the lumbar spine. The influence of age, diagnosis, and procedure. J Bone Joint Surg [Am] 1992;74-A(4):536-43.
346. Herkowitz HN, Kurz LT. Degenerative lumbar spondylolisthesis with spinal stenosis. J Bone Joint Surg [Am] 1991 July;73-A(6):802-8.
347. Johnsson KE, Rosén I, Udén A. The natural course of lumbar spinal stenosis. Acta Orthop Scand 1990;61(Suppl)237:24.
348. Katz JN, Lipson SJ, Larson MG, McInnes JM, Fossel AH, Liang MH. The outcome of decompressive laminectomy for degenerative lumbar stenosis. J Bone Joint Surg [Am] 1991 July;73-A(6):809-16.
349. Lee CK, deBari A. Lumbosacral spinal fusion with Knodt distraction rods. Spine 1986 May;11(4):373-5.
350. White AH, von Rogov P, Zucherman J, Heiden D. Lumbar laminectomy for herniated disc: a prospective controlled comparison with internal fixation fusion. Spine 1987 Apr;12(3):305-7.
351. Turner JA, Ersek M, Herron L, Haselkorn J, Kent D, Ciol MA, Deyo R. Patient outcomes after lumbar spinal fusions. JAMA 1992 Aug 19;268(7):907-11.
352. Bigos SJ, Battié MC, Spengler DM, Fisher LD, Fordyce WE, Hansson TH, Nachemson AL, Zeh J. A longitudinal, prospective study of industrial back injury reporting. Clin Orthop 1992 Jun;(279):21-34.
353. Eie N. Comparison of the results in patients operated upon for ruptured lumbar discs with and without spinal fusion. Acta Neurochir 1978;41:107-13.
354. Frymoyer JW, Hanley E, Howe J, Kuhlmann D, Matteri R. Disc excision and spine fusion in the management of lumbar disc disease. Spine 1978 Mar;3(1):1-6.
355. Schofferman J, Anderson D, Hines R, Smith G, White A. Childhood psychological trauma correlates with unsuccessful lumbar spine surgery. Spine 1992 Jun;17(6S):S138-44.
356. Vaughan PA, Malcolm BW, Maistrelli GL. Results of L4-L5 disc excision alone versus disc excision and fusion. Spine 1988 Jun;13(6):690-5.
357. Waddell G. Biopsychosocial analysis of low back pain. Baillieres Clin Rheumatol 1992 Oct;6(3):523-57.
358. Bigos SJ, Battié MC, Spengler DM, Fisher LD, Fordyce WE, Hansson T Nachemson AL, Wortley MD. A prospective study of work perceptions and psychosocial factors affecting the report of back injury. Spine 1991;16(1):1-6.
359. Skovron ML, Szpalski M, Nordin M, Melot C, Cukier D. Sociocultural factors and back pain. A population-based study in Belgian adults. Spine 1994 Jan 15;19(2):129-37.
360. Wiltse LL, Rocchio PD. Preoperative psychological tests as predictors of success of chemonucleolysis in the treatment of the low-back syndrome. J Bone Joint Surg [Am] 1975 Jun;57(4):478-83.