# Panel Members

- Stanley J. Bigos, MD
- Chair
- University of Washington
- Seattle, Washington
- Orthopedic Surgeon

- Reverend O. Richard Bowyer
- Fairmont State College
- Fairmont, West Virginia
- Consumer Representative

- G. Richard Braen, MD
- State University of New York
- Buffalo, New York
- Emergency Medicine Physician

- Kathleen Brown, PhD, RN
- University of Alabama
- Birmingham, Alabama
- Occupational Health Nurse

- Richard Deyo, MD, MPH
- University of Washington
- Seattle, Washington
- General Internist

- Scott Haldeman, DC, MD, PhD
- University of California at Irvine
- Santa Ana, California
- Neurologist/Chiropractor

- John L. Hart, DO
- Still Regional Medical Center
- Columbia, Missouri
- Physiatrist

- Ernest W. Johnson, MD
- Ohio State University
- Columbus, Ohio
- Physiatrist

- Robert Keller, MD
- Maine Medical Assessment Foundation
- Belfast, Maine
- Orthopedic Surgeon

- Daniel Kido, MD, FACR
- Washington University Medical Center
- St. Louis, Missouri
- Radiologist

- Matthew H. Liang, MD, MPH
- Harvard Medical School
- Boston, Massachusetts
- Rheumatologist

- Roger M. Nelson, PT, PhD
- Thomas Jefferson University College of Allied Health Sciences
- Philadelphia, Pennsylvania
- Physical Therapist

- Margareta Nordin, RPT, DrSci
- Hospital for Joint Diseases
- New York, New York
- Physical Therapist/Orthopedic Researcher

- Bernice D. Owen, PhD, RN
- University of Wisconsin
- Madison, Wisconsin
- Community Health Nurse

- Malcolm H. Pope, DrMedSc, PhD
- University of Vermont
- Burlington, Vermont
- Orthopedic Researcher

- Richard K. Schwartz, MS, OTR, FSR
- San Antonio, Texas
- Occupational Therapist

- Donald H. Stewart, Jr., MD
- Arlington, Virginia
- Neurosurgeon

- Jeff Susman, MD
- University of Nebraska Medical Center
- Omaha, Nebraska
- Family Physician

- John J. Triano, MA, DC
- Texas Back Institute
- Plano, Texas
- Chiropractor

- Lucius C. Tripp, MD, MPH, FACPM
- General Motors-Henry Ford Hospital Rehabilitation Center
- Warren, Michigan
- Neurosurgeon/Occupational Medicine Specialist

- Dennis C. Turk, PhD
- University of Pittsburgh School of Medicine
- Pittsburgh, Pennsylvania
- Psychologist

- Clark Watts, MD, JD
- University of Texas Health Sciences Center
- San Antonio, Texas
- Neurosurgeon

- James N. Weinstein, DO
- University of Iowa Hospitals
- Iowa City, Iowa
- Orthopedic Surgeon