# Acute Lower Back Problems in Adults

- Stanley J. Bigos, MD (Chair)
- Rev. O. Richard Bowyer
- G. Richard Braen, MD
- Kathleen Brown, PhD, RN
- Richard Deyo, MD, MPH
- Scott Haldeman, DC, MD, PhD
- John L. Hart, DO
- Ernest W. Johnson, MD
- Robert Keller, MD
- Daniel Kido, MD, FACR
- Matthew H. Liang, MD, MPH
- Roger M. Nelson, PT, PhD
- Margareta Nordin, RPT, DrSci
- Bernice D. Owen, PhD, RN
- Malcolm H. Pope, DrMedSc, PhD
- Richard K. Schwartz, MS, OTR, FSR
- Donald H. Stewart, Jr., MD
- Jeff Susman, MD
- John J. Triano, MA, DC
- Lucius C. Tripp, MD, MPH, FACPM
- Dennis C. Turk, PhD
- Clark Watts, MD, JD
- James N. Weinstein, DO
- U.S. Department of Health and Human Services
- Public Health Service
- Agency for Health Care Policy and Research
- Rockville, Maryland
- AHCPR Publication No. 95-0642
- December 1994