# References

Alho OP, Kilkku O, Oja H, et al. Control of the temporal aspect when considering risk factors for acute otitis media. Arch Otolaryngol Head Neck Surg. 1993;119:444-9. [pmid: 8457307].
Alho OP, Koivu M, Hartikainen-Sorri M, Rantakallio P. Risk factors for recurrent acute otitis media and respiratory infection in infancy. Int J Pediatr Otorhinolaryngol. 1990 Jun;19(2):151-61. [pmid: 2373599].
American Academy of Pediatrics Committee on School Health. Impedance bridge (tympanometer) as a screening device in schools. Pediatrics. 1987 Mar;79(3).
Arcand P, Gauthier P, Bilodeau G, Chapados G, Abela A, Desjardins R, Gagnon PP, Guerguerian AJ. Post-myringotomy care: a prospective study. J Otolaryngol. 1984;13(5):305-8. [pmid: 6085804].
Avery CA, Gates GA, Prihoda TJ. Efficacy of acoustic reflectometry in detecting middle ear effusion. Ann Otol Rhinol Laryngol. 1986;95:472-6. [pmid: 3532904].
Babonis TR, Weir MR, Kelly PC. Impedance tympanometry and acoustic reflectometry at myringotomy. Pediatrics. 1991;87(4):475-80. [pmid: 2011423].
Baldwin RL, Aland J. The effects of povidone-iodine preparation on the incidence of post-tympanostomy tube otorrhea. Otolaryngol Head Neck Surg. 1990 Jun;102(6):631-3. [pmid: 2115648].
Balkany TJ, Arenberg IK, Steenerson RL. Ventilation tube surgery and middle ear irrigation. Laryngoscope. 1986;96(5):529-32. [pmid: 3517534].
Ben-David J, Podoshin L, Fradis M. Tympanometry and audiometry in diagnosis of middle-ear effusions. Ear Nose Throat J. 1981;60(3):120-3. [pmid: 7194176].
Berman S, Grose K, Zerbe GO. Medical management of chronic middle ear effusion. Am J Dis Child. 1987 Jun;141:690-4. [pmid: 3554985].
Berman S, Grose K, Nuss R, Huber-Navin C, Roark R, Gabbard SA, Bagnall T. Management of chronic middle ear effusion with prednisone combined with trimethoprim-sulfamethoxazole. Pediatr Infect Dis J. 1990;9(8):533-8. [pmid: 2235167].
Bernstein JM, Reisman R. The role of acute hypersensitivity in secretory otitis media. Trans Am Acad Ophthalmol Otolaryngol. 1974 May-June;78(3):120-7.
Bernstein JM, Lee J, Conboy K, Ellis E, Li P. The role of IgE mediated hypersensitivity in recurrent otitis media with effusion. Am J Otol. 1983 July;5(1):66-9. [pmid: 6683937].
Birch L, Elbrond O. Prospective epidemiological study of common colds and secretory otitis media. Clin Otolaryngol. 1987 Feb;12(1):45-8. [pmid: 3493864].
Black N. The aetiology of glue ear-a case-control study. Int J Pediatr Otorhinolaryngol. 1985;9(2):121-33. [pmid: 4040897].
Bluestone CD, Beery QC, Paradise JL. Audiometry and tympanometry in relation to middle ear effusions in children. Laryngoscope. 1973;83(4):594-604. [pmid: 4700869].
Bluestone CD, Klein JO. Otitis media in infants and children. Philadelphia: WB Saunders. 1988.
Bluestone CD, Klein JO. Methods of examination: clinical examination. In Bluestone CD, Stool SE, editors. Pediatric Otolaryngology, 2nd ed. Philadelphia: WB Saunders. 1990,.
Boedts D, de Groote G, van Vuchelen J. Atopic allergy and otitis media with effusion. Acta Otolaryngol (Stockh). 1984;;(suppl.414):108-14.
Brookhouser PE, Goldgar DE. Medical profile of the language-delayed child: otitis-prone versus otitis-free. Int J Pediatr Otorhinolaryngol. 1987;(12):237-71. [pmid: 3583581].
Brostoff C, Cantekin EI. Observer invariant diagnosis of middle ear effusion. In Lim D, et al., editors. Recent Advances in Otitis Media: Proceedings of the Fourth International Symposium. Bar Harbor, Maine: BC Decker. 1988:47-9.
Cantekin EI. Algorithm for the diagnosis of otitis media with effusion. Ann Otol Rhinol Laryngol. 1983;92(suppl 107).
Cantekin EI, Beery QC, Bluestone CD. Tympanometric patterns found in middle ear effusions. Ann Otol Rhinol Laryngol Suppl. 1977;86(4):16-20. [pmid: 407828].
Cantekin EI, Mandel EM, Bluestone CD, Rockette HE, Paradise JL, Stool SE, Fria TJ, Rogers KD. Lack of efficacy of a decongestant-antihistamine combination for otitis media with effusion ("secretory" otitis media) in children: results of a double-blind, randomized trial. N Engl J Med. 1983;;308(6):297-301. [pmid: 6337322].
Cantekin EI, McGuire TW, Griffith TL. Antimicrobial therapy of otitis media with effusion (secretory otitis media). JAMA. 1991 Dec 18;26:(23):3309-17.
Casselbrant ML, Brostoff LM, Cantekin EI, Flaherty MR, Doyle WJ, Bluestone CD, Fria TJ. Otitis media with effusion in preschool children. Laryngoscope. 1985 Apr;95:428-36. [pmid: 4039020].
Casselbrant ML, Brostoff LM, Cantekin EI, Ashoff VM, Bluestone CD. Otitis media in children in the United States. In Sade J, editor. Acute secretory otitis media. Proceedings of the International Conference on Acute and Secretory Otitis Media, Part 1, Jerusalem, Israel, 17-22. November 1985. Amsterdam: Kugler Publications;1986:161-4.
Chan KH, Mandel EM, Rockette HE, Bluestone CD, Bass LW, Blatter MM, Breck JM, Reisinger KS, Wolfson JH, Wucher FP, et al. A comparative study of amoxicillin-clavulanate and amoxicillin: treatment of otitis media with effusion. Arch Otolaryngol Head Neck Surg. 1988;114(2):142-6. [pmid: 3276343].
Chandra RK. Prospective studies of the effect of breast feeding on incidence of infection and allergy. Acta Paediatr Scand. 1979;68(5):691-4. [pmid: 118634].
Combs JT. Predictive value of the angle of acoustic reflectometry. Pediatr Infect Dis J. 1991 Mar;10(3):214-6. [pmid: 2041669].
Corwin MJ, Weiner LB, Daniels D. Efficacy of oral antibiotics for the treatment of persistent otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1986;11(2):109-12. [pmid: 3488978].
Cunningham AS. Morbidity in breast-fed and artificially fed infants. J Pediatr. 1979;95:685-9. [pmid: 490234].
Daly K, Giebink GS, Batalden PB, Anderson RS, Le CT, Lindgren B. Resolution of otitis media with effusion with the use of a stepped treatment regimen of trimethoprim-sulfamethoxazole and prednisone. Pediatr Infect Dis J. 1991;10(7):500-6. [pmid: 1876465].
Daly K, Giebink GS, Le CT, Lindgren B, Batalden PB, Anderson RS, Russ JN. Determining risk for chronic otitis media with effusion. Pediatr Infect Dis J. 1988;7(7):471-5. [pmid: 3405649].
deCastro FJ, Jaeger RW, Martin L, Temeck JW, Tournour B. Serous otitis media: a double-blind trial with sulfisoxazole. Mo Med. 1982 Sep;629-30.
Dempster JH, MacKenzie K. Tympanometry in the detection of hearing impairments associated with otitis media with effusion. Clin Otolaryngol. 1991;;16(2):157-9. [pmid: 2070532].
Derkay CS. Pediatric otolaryngology procedures in the United States: 1977-1987. Int J Pediatr Otorhinolaryngol. 1993;;25:1-12. [pmid: 8436452].
Drug Red Book 1991. Oradell NJ: Medical Economics Co. 1991.
Duncan B, Ey J, Holberg CJ, Wright AL, Martinez FD, Taussig LM. Exclusive breast-feeding for at least 4 months protects against otitis media. Pediatrics. 1993 May;;91(5):867-72. [pmid: 8474804].
Dusdieker LB, Smith G, Booth BM, Woodhead JC, Milavetz G. The long-term outcome of nonsuppurative otitis media with effusion. Clin Pediatr. 1985;24(4):181-6.
Eddy DM. Assessing Health Practices and Designing Practice Policies: The Explicit Approach. Philadelphia, PA: American College of Physicians. 1992.
Eddy DM, Hasselblad V. Fast*Pro. Academic Press. San Diego, CA;1992.
Ernstson S, Anari M. Cefaclor in the treatment of otitis media with effusion. Acta Otolarygnol (Stockh) Suppl 1985;424:17-21. [pmid: 3865493].
Etzel RA, Pattishall EN, Haley NJ, Fletcher RH, Henderson FW. Passive smoking and middle ear effusion among children in day care. Pediatrics. 1992 Aug;90(2):228-32. [pmid: 1641287].
Feagans L, Sanyal M, Henderson F, Collier A, Appelbaum MA. The relationship of middle ear disease in [early] childhood to later expressive language narrative and attention skills. J Pediatr Psychol. 1987;;12:581-95. [pmid: 3430288].
Fiellau-Nikolajsen M. Tympanometry in 3-year-old children. Type of care as an epidemiological factor in secretory otitis media and tubal dysfunction in unselected populations of 3-year-old children. ORL J Otorhinolaryngol Relat Spec. 1979;41(4):193-205.
Fiellau-Nikolajsen M. Serial tympanometry and middle ear status in 3-year-old children. ORL J Otorhinolaryngol. 1980a;42(4):220-32.
Fiellau-Nikolajsen M. Tympanometry in three-year-old children. Prevalence and spontaneous course of middle ear effusion. Ann Otol Rhinol Laryngol Suppl. 1980b May-Jun;89(3 Pt 2):223-7.
Fria TJ, Cantekin EI, Eichler JA. Hearing acuity of children with otitis media with effusion. Arch Otolaryngol. 1985;111(1):1-6.
Friel-Patti S, Finitzo T. Language learning in a prospective study of otitis media with effusion in the first two years of life. J Speech Hear Res. 1990;33:188-94. [pmid: 2314079].
Friel-Patti S, Finitzo-Hieber T, Conti G, Brown KC. Language delay in infants associated with middle ear disease and mild fluctuating hearing impairment. Pediatr Infect Dis. 1982;1:104-9. [pmid: 7177899].
Gates GA, Avery CA, Cooper JC Jr, Prihoda TJ. Chronic secretory otitis media: effects of surgical management. Ann Otol Rhinol Laryngol Suppl. 1989;138:2-32. [pmid: 2492178].
Gates GA, Avery C, Prihoda TJ, Holt GR. Post-tympanostomy otorrhea. Laryngoscope. 1986;96(6):630-4. [pmid: 3713407].
Gates GA, Avery C, Prihoda TJ, Holt GR. Delayed onset post-tympanotomy otorrhea. Otolaryngol Head Neck Surg. 1988;98(2):111-5. [pmid: 3128752].
Giebink GS, Batalden PB, Le CT, Lassman FM, Buran DJ, Seltz AE. A controlled trial comparing three treatments for chronic otitis media with effusion. Pediatr Infect Dis J. 1990;9(1):33-40. [pmid: 2405348].
Gravel JS, Wallace IF. Listening and language at 4 years of age: effects of early otitis media. J Speech Hear Res.
Hall JW, Grose JH. The effect of otitis media with effusion on the masking level difference and the auditory brainstem response. J Speech Hear Res. 1993 Feb;36:210-17. [pmid: 8450661].
Hall LJ, Lukat RM. Results of allergy treatment on the eustachian tube in chronic serous otitis media. Am J Otol. 1981 Oct;;3(2):116-21. [pmid: 7197884].
Hardy G. Otitis media with effusion in children. South Med J. 1961;54. [pmid: 13904648].
Haugeto OK, Schroeder KE, Mair IW. Secretory otitis media, oral decongestant and antihistamine. J Otolaryngol. 1981;;10(5):350-62.
Healy GB. Antimicrobial therapy of chronic otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1984;8(1):13-7. [pmid: 6389394].
Henderson JA. Freestanding outpatient surgery centers: a market in transition. Health Industry Today. 1986;8.
Hinton AE. Surgery for otitis media with effusion in children and its relationship to parental smoking. J Laryngol Otol. 1989 June;103:559-61. [pmid: 2769020].
Holm VA, Kunze LH. Effect of chronic otitis media on language and speech development. Pediatrics. 1969 May;43(5). [pmid: 5769509].
Hurst DS. Allergy management of refractory serous otitis media. Otolaryngol Head Neck Surg. 1990 June;102(6):664-9. [pmid: 2115652].
Iverson M, Birch L, Lundqvist GR, Elbrond O. Middle ear effusion in children and the indoor environment: an epidemiological study. Arch Environ Health. 1985;40.
Jerger J. Clinical experience with impedance audiometry. Arch Otolaryngol. 1970;92:311-24. [pmid: 5455571].
Jerger J, Anthony L, Jerger S, Crump B. Studies in impedance audiometry. II. Middle ear disorders. Arch Otolaryngol. 1974;99:165-71.
Kaleida PH, Stool SE. Assessment of otoscopists' accuracy regarding middle-ear effusion. Am J Dis Child. 1992;146:433-5. [pmid: 1558077].
Kapur YP. Serous otitis media in children. Arch Otolaryngol. 1964;79. [pmid: 14063798].
Karma PH, Penttila MA, Sipila MM, Kataja MJ. Otoscopic diagnosis of middle ear effusion in acute and non-acute otitis media. I. The value of different otoscopic findings. Int J Pediatr Otorhinolaryngol. 1989;;17:27-49.
Kilby D, Richards SH, Hart G. Grommets and glue ears: two-year results. J Laryngol Otol. 1972;;86(9):881-8. [pmid: 5070299].
Kokko E, Tauno P. Palva T. Clinical results and complications of tympanostomy. Ann Otol Rhinol Laryngol. 1976;85(suppl 25):277-9. [pmid: 1267359].
Kraemer MJ, Richardson MA, Weiss NS, Furukawa CT, Shapiro GG, Pierson WE, Bierman CW. Risk factors for persistent middle-ear effusions: otitis media, catarrh, cigarette smoke exposure, and atopy. JAMA. 1983 Feb 25;249(8):1022-5. [pmid: 6681641].
Lambert PR. Oral steroid therapy for chronic middle ear perfusion: a double-blind crossover study. Otolaryngol Head Neck Surg. 1986;95(2):193-9. [pmid: 3108758].
Lampe RM, Weir MR, Spier J, Rhodes MF. Acoustic reflectometry in the detection of middle ear effusion. Pediatrics. 1985;76(1):75-8. [pmid: 4040237].
Le CT, Daly KA, Lindgren BR, Giebink GS. A clinical profile of otitis media. Arch Otolaryngol Head Neck Surg. 1992;118:1225-8. [pmid: 1418901].
Lildholdt T. Ventilation tubes in secretory otitis media. A randomized, controlled study of the course, the complications, and the sequelae of ventilation tubes. Acta Otolaryngol (Stockh) Suppl. 1983;398:1-28.
Lildholdt T, Kortholm B. Beclomethasone nasal spray in the treatment of middle-ear effusion: a double-blind study. Int J Pediatr Otorhinolaryngol. 1982;4(2):133-7. [pmid: 6752070].
Liu YS, Lang R, Lim DJ, Birck HG. Microorganisms in chronic otitis media with effusion. Ann Otol Rhinol Laryngol. 1976;85(suppl 25):245-9. [pmid: 5041].
Lous J, Fiellau-Nikolajsen M, Jeppesen AL. Secretory otitis media and language development: a six-year follow-up study with case-control. Int J Pediatr Otorhinolaryngol. 1988;;15:185-203. [pmid: 3397239].
Macknin ML, Jones PK. Oral dexamethasone for the treatment of persistent middle ear effusion. Pediatrics. 1985;75(2):329-35. [pmid: 4038553].
Mandel EM, Rockette HE, Bluestone CD, Paradise JL, Nozza RJ. Efficacy of amoxicillin with and without decongestant-antihistamine for otitis media with effusion in children: results of a double-blind, randomized trial. N Engl J Med. 1987;;316:432-7. [pmid: 2880294].
Mandel EM, Rockette HE, Paradise JL, Bluestone CD, Nozza RJ. Comparative efficacy of erythromycin-sulfisoxazole, cefaclor, amoxicillin, or placebo for otitis media with effusion in children. Pediatr Infect Dis J. 1991 Dec;10(12):899-906. [pmid: 1766705].
Markowitz-Spence L, Brodsky L, Syed N, Stanievich J, Volk M. Anesthetic complications of tympanotomy tube placement in children. Arch Otolaryngol Head Neck Surg. 1990;116:809-12. [pmid: 2363918].
Marks NJ, Mills RP, Shaheen OH. A controlled trial of cotrimoxazole therapy in serous otitis media. J Laryngol Otol. 1981 Oct;95:1003-10. [pmid: 7028896].
Matkin ND. The child with a marked high-frequency hearing impairment. Pediatr Clin North Am. 1968 Aug;15(3):677-90. [pmid: 4970367].
Maw AR. Chronic otitis media with effusion and adeno-tonsillectomy-a prospective randomized controlled study. Int J Pediatr Otorhinolaryngol. 1983;;6(3):239-46. [pmid: 6373644].
Maw AR. Development of tympanosclerosis in children with otitis media with effusion and ventilation tubes. J Laryngol Otol. 1991;105(8):614-7. [pmid: 1919311].
Maw R, Bawden R. Spontaneous resolution of severe chronic glue ear in children and the effect of adenoidectomy, tonsillectomy, and insertion of ventilation tubes (grommets). Br Med J. 1993;306:756-60. [pmid: 8490338]. [pmcid: 1677213].
Maw AR, Herod F. Otoscopic impedance and audiometric findings in glue ear treated by adenoidectomy and tonsillectomy. A prospective randomized study. Lancet. 1986;1(8495):1399-1402.
Moller P, Dingser G. Dingsor G. Otitis media with effusion: can erythromycin reduce the need for ventilating tubes?. J Laryngol Otol 1990. 104(3):200-2.
Mosbech H, Dirksen A, Dreborg S, Frolund L, Heinig JH, Svendsen UG, Soborg M, Taudorf E, Weeke B. Hyposensitization in asthmatics with mPEG-modified and unmodified house dust mite extract. IV. Occurrence and prediction of side effects. Allergy. 1990 Feb;45(2):142-50. [pmid: 2316824].
Motoyama EK. Safety and outcome in pediatric anesthesia. In Motoyama EK, Davis PJ. Smith's Anesthesia for Infants and Children, 5th ed. St. Louis: CV Mosby. 1990:847-56.
Mueller HL. Allergy in Children. Philadelphia: WB Saunders Co, 1970.
Niederman LG, Walter-Buchholtz V, Jabalay T. A comparative trial of steroids versus placebos for treatment of chronic otitis media with effusion. In: Proceedings of the 4th International Symposium on Recent Advances in Otitis Media. Burlington, Ontario: BC Decker Inc;1988:273-5.
Nober EH. Articulation of the deaf. Except Child. 1967 May;33(9):611-21. [pmid: 6042707].
Orchik DJ, Morff R, Dunn JW. Middle ear status at myringotomy and its relationship to middle ear immitance measurements. Ear Hear. 1980;1(6):324-8. [pmid: 7192227].
Ostergaard PA, Kaad PH, Kristensen T. A prospective study on the safety of immunotherapy in children with severe asthma. Allergy. 1986 Nov;41(8):588-93. [pmid: 3544937].
Oyler RF, Oyler AL, Matkin ND. A unilateral hearing loss may be detrimental to a child's academic career. Hear J. 1987;:19-21.
Paine R, Coble RJ. Breast-feeding and infant health in a rural US community. Am J Dis Child. 1982 Jan;136(1):36-8. [pmid: 7055108].
Paradise JL, Smith CG, Bluestone CD. Tympanometric detection of middle ear effusion in infants and young children. Pediatrics. 1976;58(2):198-210. [pmid: 951134].
Persico M, Podoshin L, Fradis M. Otitis media with effusion: a steroid and antibiotic therapeutic trial before surgery. Ann Otol. 1987;87:191-5.
Pillsbury HC III, Grose JH, Hall JW III. Otitis media with effusion in children. Binaural hearing before and after corrective surgery. Arch Otolaryngol Head Neck Surg. 1991;117:718-22.
Podoshin L, Fradis M, Ben-David Y, Faraggi D. The efficacy of oral steroids in the treatment of persistent otitis media with effusion. Arch Otolaryngol Head Neck Surg. 1990;;116(12):1404-6. [pmid: 2248740].
Politzer A. A Text-Book of the Diseases of the Ear for Students and Practitioners, 5th ed. London: Bailliere, Tindall & Cox. 1909.
Pratt LW. Tonsillectomy and adenoidectomy: mortality and morbidity. Trans Am Acad Ophthalmol Otolaryngol. 1970;;74:1146-50. [pmid: 5493402].
Rach GH, Zielhuis GA, van den Broek P. The influence of chronic persistent otitis media with effusion on language development in 2- to 4-year olds. Int J Pediatr Otorhinolaryngol. 1988;15:253-61. [pmid: 3192363].
Rach GH, Zielhuis GA, van Baarle PW, van den Broek P. The effect of treatment with ventilating tubes on language development in preschool children with otitis media with effusion. Clin Otolaryngol. 1991;;16:128-32. [pmid: 2070526].
Rasmussen F. Protracted secretory otitis media. The impact of familial factors and day-care center attendance. Int J Pediatr Otorhinolaryngol. 1993 Feb;26(1):29-37.
Roberts JE, Burchinal MR, Collier AM, Ramey CT, Koch MA, Henderson FW. Otitis media in early childhood and cognitive, academic, and classroom performance of the school-aged child. Pediatrics. 1989;83(4):477-85. [pmid: 2927985].
Roberts JE, Burchinal MR, Davis BP, Collier AM, Henderson FW. Otitis media in early childhood and later language. J Speech Hear Res. 1991;34:1158-68. [pmid: 1749246].
Roberts JE, Burchinal MR, Koch MA, Footo MM, Henderson FW. Otitis media in early childhood and its relationship to later phonological development. J Speech Hear Disord. 1988;;53:416-24. [pmid: 3184902].
Roberts JE, Sanyal MA, Burchinal MR, Collier AM, Ramey CT, Henderson FW. Otitis media in early childhood and its relationship to later verbal and academic performance. Pediatrics. 1986;78(3):423-30. [pmid: 3748675].
Robinson JW, Nicholas HO. Catarrhal otitis media with effusion. South Med J. 1951;44.
Roland PS, Finitzo T, Friel-Patti S, Brown KC, Stephens KT, Brown O, Coleman JM. Otitis media: incidence, duration, and hearing status. Arch Otolaryngol Head Neck Surg. 1989;115(9):1049-53. [pmid: 2765220].
Rosenfeld RM, Mandel EM, Bluestone CD. Systemic steroids for otitis media with effusion in children. Arch Otolaryngol Head Neck Surg. 1991 Sept;;117:984-9. [pmid: 1832876].
Rosenfeld RM, Post JC. Meta-analysis of antibiotics for the treatment of otitis media with effusion. Otolaryngol Head Neck Surg. 1992;106:378-86. [pmid: 1533027].
Rowe-Jones JM, Brockbank MJ. Parental smoking and persistent otitis media with effusion in children. Int J Pediatr Otorhinolaryngol. 1992;;24:19-24. [pmid: 1399300].
Saarinen UM. Prolonged breast feeding as prophylaxis for recurrent otitis media. Acta Paediatr Scand. 1982;71:567-71. [pmid: 7136672].
Schappert SM. Office visits for otitis media: United States, 1975-90. Advance Data from Vital and Health Statistics of the Centers for Disease Control/National Center for Health Statistics, U.S. Department of Health and Human Services, No. 214. September 8. 1992.
Schloss MD, Dempsey EE, Rishikof E, Sorger S, Grace MGA. Double blind study comparing erythromycin-sulfisoxazole (Pediazole) TID to placebo in chronic otitis media with effusion. 1988. Burlington, Ontario: BC Decker Inc;In: Proceedings of the 4th International Symposium on Recent Advances in Otitis Media:261-3.
Schuknecht HF. Serous otitis media in childhood: a new treatment. Clin Pediatr. 1964;37.
Schwartz RH, Puglese J, Schwartz DM. Use of a short course of prednisone for treating middle ear effusion: a double-blind crossover study. Ann Otol Rhinol Laryngol. 1980;89:296-300. [pmid: 7416678].
Schwartz RH, Rodriguez WJ. Trimethoprim-sulfamethoxazole treatment of persistent otitis media with effusion. Pediatr Infect Dis J. 1982;1(5):333-5.
Senturia BH, Jessert CF, Carr CD, Baumann ES. Studies concerned with tubal tympanitis. Ann Otol Rhinol Laryngol. 1958;;67. [pmid: 13571868].
Shambaugh GE (moderator). Panel discussion: serous effusion of the middle ear. Laryngoscope. 1975;;85.
Shurin PA, Pelton SI, Finkelstein J. Tympanometry in the diagnosis of middle-ear effusion. N Engl J Med. 1977;;296(8):412-7. [pmid: 834211].
Silva PA, Chalmers D, Stewart I. Some audiological, psychological, educational and behavioral characteristics of children with bilateral otitis media with effusion: a longitudinal study. J Learning Disabilities. 1986;19(3):165-9.
Silva PA, Kirkland C, Simpson A, Stewart IA, Williams SM. Some developmental and behavioral problems associated with bilateral otitis media with effusion. J Learning Disabilities. 1982;15(7):417-21.
Skinner DW, Lesser TH, Richards SH. A 15 year follow-up of a controlled trial of the use of grommets in glue ear. Clin Otolaryngol. 1988;13(5):341-6. [pmid: 3243009].
Sorensen CH, Holm-Jensen S, Tos M. The post-winter prevalence rate of middle ear effusion in four-year-old children, judged by tympanometry. Int J Pediatr Otorhinolaryngol. 1981;3:119-28. [pmid: 7287314].
Strachan DP, Jarvis MJ, Feyerabend C. Passive smoking, salivary cotinine concentrations, and middle ear effusion in 7 year old children. Br Med J. 1989;298:1549-52. [pmid: 2503113]. [pmcid: 1836817].
Suehs OW. Serous otitis media. Laryngoscope. 1952;62. [pmid: 12982015].
Sundberg L. Antibiotic treatment of secretory otitis media. Acta Otolaryngol (Stockh). 1984;407(suppl):26-9.
Sundberg L, Eden T, Ernstson S, Cederberg A. Tissue penetration of erythromycin in Waldeyer's ring and bacteriology of secretory otitis media. Acta Otolaryngol Suppl 384. 1981.
Tainio V-M, Savilahti E, Salmenpera L, Arjomaa P, Siimes MA, Perheentupa J. Risk factors for infantile recurrent otitis media: atopy but not type of feeding. Pediatr Res. 1988;23(5):509-12. [pmid: 3387173].
Teele DW, Healy GB, Tally FP. Persistent effusions of the middle ear. Cultures for anaerobic bacteria. Ann Otol Rhinol Laryngol. 1980;89:102-3.
Teele DW, Klein JO, Chase C, Menyuk P, Rosner B; the Greater Boston Otitis Media Study Group. Otitis media in infancy and intellectual ability, school achievement, speech, and language at age 7 years. J Infect Dis. 1990;162:685-94. [pmid: 2387994].
Teele DW, Klein JO, Rosner B. Epidemiology of otitis media during the first seven years of life in children in greater Boston. J Infect Dis. 1989;160:83-94. [pmid: 2732519].
Teele DW, Klein JO, Rosner B; the Greater Boston Otitis Media Study Group. Middle ear disease and the practice of pediatrics. Burden during the first five years of life JAMA 1983 Feb 25 249(8) 1026 9[AUTH]+AND+Klein+ti=middle+ear+disease+practice">[AUTH]+AND+middle+ear+disease+practice">6823056
Teele DW, Klein JO, Rosner B; the Greater Boston Otitis Media Study Group. Otitis media with effusion during the first three years of life and development of speech and language. Pediatrics. 1984;;74(2):282-7. [pmid: 6540437].
Teele DW, Teele J. Detection of middle ear effusion by acoustic reflectometry. J Pediatr. 1984;;104(6):832-8. [pmid: 6539374].
Thomsen J, Sederberg-Olsen J, Balle V, Vejlsgaard R, Stangerup SE, Bondesson G. Antibiotic treatment of children with secretory otitis media: a randomized, double-blind, placebo-controlled study. Arch Otolaryngol Head Neck Surg. 1989;115(4):447-51. [pmid: 2647105].
Timmermans SF, Gerson S. Chronic granulomatous otitis media in bottle-fed Inuit children. Can Med Assoc J. 1980;;22(5):545-7.
Tomonaga K, Kurono Y, Mogi G. The role of nasal allergy in otitis media with effusion: a clinical study. Acta Otolaryngol (Stockh). 1988;(suppl. 458):41-7.
Toner JG, Mains B. Pneumatic otoscopy and tympanometry in the detection of middle ear effusion. Clin Otolaryngol. 1990;15(2):121-3. [pmid: 2350887].
Tos M, Poulsen G, Borch J. Tympanometry in 2-year-old children. ORL J Otorhinolaryngol. 1978;40(2):77-85.
van Cauwenberge P, Cauwe F, Kluyskens P. The long-term results of the treatment with transtympanic ventilation tubes in children with chronic secretory otitis media. Int J Pediatr Otorhinolaryngol. 1979;1:109-16. [pmid: 576016].
Varsano I, Volovitz B, Mimouni F. Sulfisoxazole prophylaxis of middle ear effusion and recurrent otitis media. Am J Dis Child. 1985 Jun;139:632-5. [pmid: 3890523].
Vayda E, Lyons D, Anderson BD. Surgery and anesthesia in Ontario. Can Med Assoc J. 1977 Jun 4;;116(11):1263-6. [pmid: 861883].
Ventry IM. Effects of conductive hearing loss: fact or fiction. J Speech Hear Disord. 1980 May;45(2):143-56. [pmid: 7442148].
Williams RL, Chalmers TC, Stange KC, Chalmers FT, Bowlin SJ. Use of antibiotics in preventing recurrent acute otitis media and in treating otitis media with effusion: a meta-analytic attempt to resolve the brouhaha. JAMA. 1993 Sep 15;;270(11):1344-51. [pmid: 8141875].
Wright PF, Sell SH, McConnell KB, Sitton AB, Thompson J, Vaughn WK, Bess FH. Impact of recurrent otitis media on middle-ear function, hearing and language. J Pediatr. 1988;113:581-7. [pmid: 3411407].
Yardley MP. Tonsillectomy, adenoidectomy and adenotonsillectomy: are they safe day case procedures? J Laryngol Otol 1992 Apr;106(4):299-300.
Zielhuis GA, Heuvelmans-Heinen EW, Rach GH, van den Broek P. Environmental risk factors for otitis media with effusion in preschool children. Scand J Prim Health Care. 1989;7(1):33-8. [pmid: 2727458].
Zielhuis GA, Rach GH, van den Broek P. Screening for otitis media with effusion in preschool children. Lancet. 1989;1(8633):311-4. [pmid: 2563465].
Zielhuis GA, Rach GH, van den Broek. The natural course of otitis media with effusion in preschool children. Eur Arch Otorhinolaryngol. 1990;247:215-21. [pmid: 2375863].
Zielhuis GA, Straatman H, Rach GH, van den Broek P. Analysis and presentation of data on the natural course of otitis media with effusion in children. Int J Epidemiol. 1990 Dec;19(4):1037-44. [pmid: 2083987].