# Executive Summary

This Guideline was developed by the American Academy of Pediatrics, under contract with the Agency for Health Care Policy and Research (AHCPR) and in consortium with the American Academy of Family Physicians and the American Academy of Otolaryngology-Head and Neck Surgery (the "Consortium"). To develop the Guideline, the Consortium, with AHCPR approval, convened an interdisciplinary non-Federal panel comprising health care professionals and a consumer representative.

The Agency for Health Care Policy and Research identified otitis media in children as a topic for clinical practice guideline development for several reasons. Otitis media has high prevalence and incidence among children in the United States. Widespread variations in practice patterns exist among generalists and specialists, and there are questions about the appropriateness and timing of treatment. Finally, the direct and indirect costs of diagnosing and managing otitis media are enormous: otitis media was the principal diagnosis for ambulatory care visits by young children, at an estimated cost of over $1 billion, in 1990-91.

The Otitis Media Guideline Panel viewed otitis media as a spectrum of diseases, ranging from acute to chronic and with or without symptoms. Otitis media can resolve spontaneously or respond to treatment. To examine issues of disease prevalence, management, and variations in treatment patterns for otitis media within the contract time frame, the Panel narrowed the scope of this Guideline to the management of otitis media with effusion in an otherwise healthy child age 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits. This choice of condition allowed the Panel to examine a spectrum of management issues, including surgery. The age range for Guideline recommendations reflects the Panel's decision to examine treatment effects on the outcome of most widespread concern: alterations in hearing and associated development of speech, language, and cognition. The ages for Guideline recommendations were expanded when the data permitted, and in many instances the recommendations may be extrapolated to older children.

This Guideline is based on the relevant scientific literature and on the Panel's expert clinical opinion to support recommendations. The Consortium applied the Agency for Health Care Policy and Research's recommended methods to develop the Guideline. Using these methods, the Panel defined the problem and identified the alternatives for its management, the target population, the clinical settings in which the Guideline is to be applied, the important health outcomes, and the relationship of the outcomes to the alternatives for management. The definition of the problem guided the literature review. A systematic computerized search of the literature on otitis media with effusion was conducted. The Panel reviewed the data, synthesized the findings, and developed Guideline recommendations. Other sources of input into the Guideline included the Panel's own expertise, information from Open Meeting presentations, peer and pilot reviewer comments, and Panel subcommittee analysis of the literature.

The Guideline addresses the following subjects:

- Natural history of otitis media with effusion.
- Functional impairments that may result from otitis media with effusion, and the difficulty of measuring the effects of medical and surgical interventions on long-term outcomes.
- Diagnosis and hearing evaluation for otitis media with effusion.
- Control of environmental risk factors that may contribute to the occurrence of the disease.
- Medical and surgical interventions for otitis media with effusion in the otherwise healthy child age 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits. Interventions considered include observation, antibiotic therapy, steroid therapy, antihistamine/decongestant therapy, myringotomy with insertion of tympanostomy tubes, adenoidectomy, tonsillectomy, and allergy management.

Based on empirical evidence and their clinical experience and judgment, the Panel makes the following recommendations for the provision of care to a target group of patients with otitis media with effusion. The Panel recognizes the clinical circumstances of individual patients can require additional judgment of health care providers and parents regarding therapy.

- Initial management for effusion includes observation OR antibiotic therapy, and control of environmental risk factors.
- Management when effusion has persisted for a total of 3 months includes hearing evaluation. If hearing is in the normal range (better than 20 decibels hearing threshold level in the better-hearing ear), management includes observation OR antibiotic therapy and control of environmental risk factors. If a bilateral hearing deficit is present (20 decibels hearing threshold level or worse in the better-hearing ear), management includes antibiotic therapy OR bilateral myringotomy with insertion of tympanostomy tubes, and control of environmental risk factors.
- Management when effusion has persisted for 4 to 6 months with a bilateral hearing loss includes bilateral myringotomy with insertion of tympanostomy tubes and control of environmental risk factors.