# Acknowledgments

The Clinical Practice Guideline on Otitis Media with Effusion in Young Children is the product of significant contributions by numerous individuals and organizations. The Otitis Media Guideline Panel and the Consortium wish to acknowledge those who provided expert and technical support.

Anthony Magit, MD, supervised the literature review and designed the literature review form. The following experts reviewed the numerous articles and abstracted the data: David A. Blandino, MD; Linda H. Carlson, RN, MSN, CPNP; Carol Zinn Congedo, MD, FACS; Alejandro Hoberman, MD; Gina Magit, MSPH; Betty Jane McWilliams, PhD; Lynn Medley, MS; George A. Modreck, MA; John Murray, MD; F. Adele Proctor, ScD; Allen F. Shaughnessy, PharmD; and Rafael Tarnopolsky, MD. Mary Scheetz and Suzanne Stewart, Children's Hospital of Pittsburgh, provided library expertise, organized and conducted the literature search, and provided assistance in referencing and developing bibliographies. David Nowels, MD, and Vic Hasselblad, PhD, reviewed and analyzed the data on antibiotic therapy for otitis media. Jeffrey Blumer, MD, assisted in obtaining data on pharmacotherapy. Darleen Conn served as administrative liaison at Children's Hospital of Pittsburgh. Gail Jones, American Academy of Family Physicians, and Amy Mayer, American Academy of Pediatrics, provided clerical assistance for the project. Jerry MacDonald and Mary Enright, American Academy of Pediatrics Accounting Department, handled financial administration of the contract. Diana Bosse Mathis helped develop drafts of the Clinical Practice Guideline, Quick Reference Guide for Clinicians, and Parent Guide, and copyedited the drafts.

The Panel and Consortium acknowledge with special gratitude the contribution of William A. Gold, MD, MPH, of Lewin-VHI, Inc., who served the Panel faithfully as health policy analyst for the Guideline cost report until his death in October 1993.