# Consortium Staff

- Hanan S. Bell, PhD
- American Academy of Family Physicians
- Kansas City, Missouri
- Methodologist
- Karin Bierstein, JD, MPH
- (until May 1993)
- Maureen T. Hannley, PhD
- (from May 1993)
- American Academy of Otolaryngology—Head and Neck Surgery
- Alexandria, Virginia
- Health Policy Coordinators
- Carla T. Herrerias, MPH
- American Academy of Pediatrics
- Elk Grove Village, Illinois
- Project Manager
- Robert H. Sebring, PhD
- American Academy of Pediatrics
- Elk Grove Village, Illinois
- Principal Investigator