# Panel Members

- Sylvan E. Stool, MD,
- Co-Chair
- Professor of Pediatrics and Otolaryngology
- University of Pittsburgh School of Medicine
- Director of Education
- Department of Pediatric Otolaryngology Children's Hospital of Pittsburgh
- Pittsburgh, Pennsylvania
- Pediatric Otolaryngologist
- Alfred O. Berg, MD, MPH,
- Co-Chair
- Professor and Associate Chair
- Department of Family Medicine University of Washington
- Seattle, Washington
- Family Physician
- Stephen Berman, MD
- Professor of Pediatrics
- University of Colorado School of Medicine
- Director, Health Policy and State Medically Indigent Programs
- University of Colorado Health Sciences Center Childrens Hospital
- Denver, Colorado
- Pediatrician
- Cynthia J. Carney
- Freelance Writer and Author
- Washington, District of Columbia
- Consumer Representative
- James R. Cooley, MD
- Clinical Instructor in Pediatrics
- Harvard Medical School
- Senior Consultant in Pediatrics Clinical Quality Management
- Harvard Community Health Plan
- Brookline, Massachusetts
- Pediatrician
- Larry Culpepper, MD, MPH
- Professor of Family Medicine
- Brown University Memorial Hospital of Rhode Island
- Pawtucket, Rhode Island
- Family Physician
- Roland D. Eavey, MD
- Associate Professor of Otology and Laryngology
- Harvard Medical School
- Director, Pediatric Otolaryngology Service
- Massachusetts Eye and Ear Infirmary
- Boston, Massachusetts
- Pediatric Otolaryngologist
- Lynne V. Feagans, PhD
- Professor of Human Development
- College of Health and Human Development The Pennsylvania State University
- University Park, Pennsylvania
- Pediatric Psychologist
- Terese Finitzo, PhD, CCC/A
- Administrative Director
- Neuroscience Center Methodist Medical Center
- Dallas, Texas
- Pediatric Audiologist
- Ellen M. Friedman, MD
- Associate Professor of Otolaryngology and Pediatrics
- Baylor College of Medicine
- Chief of Pediatric Otolaryngology
- Texas Children's Hospital
- Houston, Texas
- Pediatric Otolaryngologist
- Janice A. Goertz, RN, BS, CPNP
- Pediatric Nurse Practitioner
- Pediatric Centers of Southwestern Michigan, PC
- Richland, Michigan
- Pediatric Nurse Practitioner
- Allan J. Goldstein, MD
- Director, Medical Affairs
- Battle Creek Health System
- Battle Creek, Michigan
- Otolaryngologist
- Kenneth M. Grundfast, MD
- Professor, Division of Otolaryngology
- George Washington University School of Medicine
- Clinical Professor of Otolaryngology-Head and Neck Surgery
- Georgetown University School of Medicine
- Chairman, Department of Otolaryngology-Head and Neck Surgery
- Children's National Medical Center
- Washington, District of Columbia
- Pediatric Otolaryngologist
- Douglas G. Long, MD
- Private Practice,
- Boothbay, Maine
- Family Physician
- Loretta L. Macconi, RN, MSN, CRNP
- School Nurse Practitioner
- Henry C. Lea School
- Philadelphia, Pennsylvania
- School Nurse Practitioner
- LoBirtha Melton, RN, BSN, MPA
- Director, Women & Children Services
- Alameda County Health Care Services Agency
- Oakland, California
- Expert Nurse, Maternal and Child Health
- Joanne Erwick Roberts, PhD, CCC-SLP & AUD
- Research Associate Professor of Speech and Hearing Sciences
- University of North Carolina at Chapel Hill
- Research Investigator
- Frank Porter Graham Child Development Center University of North Carolina at Chapel Hill
- Speech-Language Pathologist
- Jessie L. Sherrod, MD, MPH
- Assistant Professor of Pediatrics and Infectious Disease
- Charles R. Drew University of Medicine and Science
- Clinical Assistant Professor of Pediatrics
- University of California at Los Angeles
- Staff Epidemiologist
- Martin Luther King, Jr., Hospital
- Los Angeles, California
- Infectious Disease Specialist
- Jane E. Sisk, PhD
- Professor, Division of Health Policy and Management
- School of Public Health Columbia University New York, New York
- Economist and Health Policy Analyst