# Foreword

The past 15 years have shown a notable increase in the number of children identified as having otitis media (inflammation of the middle ear). According to the National Center for Health Statistics, otitis media is the most common diagnosis for physician office visits by children under age 15. Office visits for otitis media increased by 150 percent between 1975 and 1990, to 24.5 million, with children under age 15 accounting for 81 percent of the visits. Children under age 2 had the highest rate of visits to physician offices for otitis media, and they also had the greatest increase in visits between 1975 and 1990: 224 percent.

Otitis media is a general term for several conditions that can affect the middle ear, ranging from acute to chronic and with or without symptoms. To follow methods for practice guideline development recommended by the Agency for Health Care Policy and Research, the topic of this Guideline was narrowed to the management of otitis media with effusion in an otherwise healthy child age 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits. This definition permitted examination of important medical and surgical interventions and their effects on long-term outcomes. In addition, 1 through 3 years is the critical age for development of speech and language, which may be affected by otitis media with effusion. The Guideline does not apply to children younger than age 12 months or, unless specifically noted, to children age 4 and above.

Otitis media with effusion is characterized by the presence of fluid in the middle ear without signs or symptoms of infection. Otitis media with effusion has also been referred to as noninfected middle ear effusion, secretory otitis media, and serous otitis media, among other terms. Although data on prevalence of otitis media with effusion as a separate condition were not available, the Panel estimated the prevalence of this condition as 25 to 35 percent of otitis media cases.

The medical interventions considered in the Guideline for management of otitis media with effusion in young children include antibiotic therapy, steroid therapy, and antihistamine/decongestant therapy; the surgical interventions studied include myringotomy with insertion of tympanostomy tubes, adenoidectomy, and tonsillectomy. Short-term outcomes addressed were resolution of effusion and restoration of hearing; the long-term outcomes studied were the effects of otitis media with effusion on hearing and hearing-related development of speech, language, and cognition. Because the prevalence of otitis media with effusion and the impact of associated hearing loss are greater among children with craniofacial or neurologic abnormalities, sensory deficits, or other medical illness, these children are excluded from Guideline recommendations.

A 1991 cost analysis of private health insurance claims, performed under contract for this Guideline, estimated direct and indirect medical management costs (physician office visits, prescription medications, parents' time lost from work) at $406 per patient episode and direct and indirect surgical treatment costs (physician office visits, parents' time lost from work, and charges for myringotomy with insertion of tympanostomy tubes) at $2,174 per patient episode.

Although otitis media with effusion is exceedingly common, and thousands of research studies have been conducted, uncertainties persist regarding its etiology and management. Most cases of otitis media with effusion resolve spontaneously, but the length of time to resolution is variable. The long-term effects of the disease are not well understood. A mild to moderate conductive hearing loss can accompany otitis media with effusion. Hearing loss associated with frequent or prolonged episodes of otitis media with effusion might affect speech and language development, behavior, cognition, and academic achievement. Other ear problems, such as tympanic membrane perforation, might also occur with prolonged or frequent episodes of otitis media with effusion.

Uncertainties about the causes, diagnosis, and appropriate treatment of otitis media with effusion are reflected in variations in clinician practice patterns. The Clinical Practice Guideline on Otitis Media with Effusion in Young Children was written in response to these and other uncertainties, outlining an approach to the management of care for young children with this condition.

This Guideline was developed by the American Academy of Pediatrics, under contract with the Agency for Health Care Policy and Research (AHCPR) and in consortium with the American Academy of Family Physicians and the American Academy of Otolaryngology-Head and Neck Surgery (the "Consortium"). To develop the Guideline, the Consortium, with AHCPR approval, convened an interdisciplinary panel of pediatricians, family physicians, otolaryngologists, an infectious disease specialist, nurses, audiologists, speech/language pathologists, psychologists, a health policy analyst, and a consumer representative. The Panel defined and structured the problem and identified the important interventions and health outcomes. A critical review of the literature was conducted. Before the literature review was completed, an Open Meeting was held to obtain additional information on managing otitis media with effusion. After a careful analysis of the data, the Panel developed draft guidelines and conducted peer and pilot reviews. Comments from these reviews were assessed and used in the development of the final Guideline.

This is the first edition of the Clinical Practice Guideline on Otitis Media with Effusion in Young Children. The Consortium recognizes that issues surrounding the management of otitis media with effusion are complex and controversial. A revised Guideline will be produced when warranted by further research.

- Otitis Media Guideline Panel