# Guideline: Other Therapies

No Recommendation: No recommendation is made regarding other therapies (chiropractic, holistic, naturopathic, traditional or indigenous, homeopathic) for the treatment of otitis media with effusion in the otherwise healthy child age 1 through 3 years.[Based on lack of scientific evidence.]

Other therapies for the treatment of otitis media with effusion include chiropractic, holistic, naturopathic, traditional or indigenous, and homeopathic methods. The frequency with which these therapies are used in the United States and their cost are not known.

The Panel was unable to find any reports of randomized controlled studies of other therapies for otitis media with effusion in young children. Attempts to locate such data included a computer search of the literature, letters to schools of education in the relevant fields, and personal communication with practitioners of other treatment methods. In addition, representatives from societies and institutes of higher education for practitioners of these methods were invited to participate in the Open Meeting and to submit written testimony on this topic.

Because none of the submitted materials reported on data obtained in controlled studies, the Panel did not make any recommendation regarding other therapies for the treatment of otitis media with effusion in children. The Panel did find, however, that some of the other therapies are apparently without notable risk of morbidity and are inexpensive. Thus, the Panel recommended that randomized controlled studies of these therapies for otitis media with effusion in children be undertaken.