# Guideline: Allergy

No Recommendation: No recommendation is made regarding allergy management as a treatment for otitis media with effusion.[Based on insufficient evidence clarifying the relationship between allergy and otitis media with effusion.]

The close anatomic relationships between the nasopharynx, eustachian tube, and middle ear have led many experts to examine the role that allergy might play in the occurrence of eustachian tube malfunction and chronic otitis media with effusion. Hall and Lukat (1981) reviewed studies of the association between otitis media with effusion and allergy, and found that three articles estimated an allergic origin of otitis media with effusion in 20 to 90 percent of cases (Hardy, 1961; Shambaugh, 1975; Mueller, 1970). However, they found that in a number of other studies allergy was shown to be of little importance in the etiology of otitis media with effusion (Robinson and Nicholas, 1951; Kapur, 1964; Schuknecht, 1964; Senturia, Jessert, Carr, et al., 1958; Suehs, 1952).

The Panel examined 22 articles in its initial review of allergy and otitis media, but the majority of these studies did not meet the Panel's criteria for inclusion in the evidence. After exclusion of case reports and studies that included adult subjects, seven articles remained, and these were descriptive rather than reports of randomized controlled studies. Because methods used in these studies to measure the association of allergy and otitis media were not commensurable, the data could not be combined for meta-analysis.

## Atopy as a Risk Factor

The Panel found six studies that examined atopy as a risk factor for otitis media with effusion. Because the results of these studies were conflicting and some patients were older than the Guideline target patient, no conclusion could be drawn from the data as a group.

No association between atopy and otitis media with effusion was found in a study reported by Black (1985).

In a Japanese study (Tomonaga, Kurono, and Mogi, 1988), researchers determined that allergic rhinitis was present in 50 percent of 259 patients (mean age 6 years) in whom otitis media with effusion had been diagnosed, and otitis media with effusion was present in 21 percent of 605 patients (mean age 9 years) in whom allergic rhinitis had been diagnosed. Among 108 children (ages 5 to 8 years, mean 6 years) in whom neither condition had been diagnosed, the incidences of allergic rhinitis, otitis media with effusion, and both of these conditions were 17 percent, 6 percent, and 2 percent, respectively.

Another study (Kraemer, Richardson, Weiss, et al., 1983) compared risk factors for persistent middle ear effusion among 76 children admitted for insertion of tympanostomy tubes and 76 controls matched by age, sex, and season of admission for a general surgical procedure. Results of this study showed a nearly fourfold increase in the risk of persistent middle ear effusion in children who had atopic symptoms for more than 15 days per month, although this statistic was uncorrected for a large number (more than 15) of other possible risk factors for otitis media with effusion. When the single risk factor of atopic symptoms for more than 1 day per month was examined, the relative risk for otitis media with effusion was only 0.5.

Bernstein, Lee, Conboy, et al. (1983) reported on a prospective study of the role of hypersensitivity mediated by immunoglobulin E in the occurrence of otitis media with effusion. Subjects for this study were 77 children age 2 to 18 years with recurrent otitis media with effusion who had undergone at least two myringotomies with insertion of tympanostomy tubes. The finding that 32 (42 percent) of the subjects had allergic rhinitis mediated by immunoglobulin E suggests that in patients with allergic rhinitis, otitis media with effusion can result from hypersensitivity mediated by immunoglobulin E. However, the middle ear might be the target organ in only 15 to 20 percent of patients with otitis media with effusion and allergic rhinitis. In this study, the middle ear was the target organ in only 5 (7 percent) of the 77 patients with recurrent otitis media with effusion. This finding, and the fact that more than half (58 percent) of children with recurrent otitis media with effusion in this study did not have allergic rhinitis and were clearly nonallergic, led the authors to conclude that the role of atopy in otitis media with effusion is still unresolved.

In another study, levels of immunoglobulin E were measured in middle ear effusions and serum samples from 58 children age 6 months to 11 years (Boedts, de Groote, and van Vuchelen, 1984). Eight (14 percent) of the 58 patients had markedly elevated serum levels of immunoglobulin E, indicating that an atopic disorder was very likely. Although the authors note that their results and those of other studies do not support allergy as a major factor in the etiology of otitis media with effusion, the results do not rule out the possibility that otitis media with effusion might occur as a complication of allergic rhinitis.

Finally, Bernstein and Reisman (1974) studied allergy in a group of 200 children who had undergone one or more myringotomies with insertion of tympanostomy tubes. They found that 24 percent (46) of the 200 had allergy but that the incidence of allergy was 35 percent among children (n=88) who had undergone more than one myringotomy with insertion of tubes. The authors concluded that the middle ear is not an allergic organ, but that middle ear disease can be secondary to allergy elsewhere in the nasopharynx. However, six patients with recurrent otitis media with effusion and known allergies did not improve with several years of aggressive allergy treatment.

## Hyposensitization as a Treatment

Two of the seven articles on allergy reported on the role of hyposensitization in otitis media with effusion (Hurst, 1990; Tomonaga, Kurono, and Mogi, 1988). Both studies were of case-control design, so that the researchers neither randomized subjects nor "blinded" clinicians as to whether patients were receiving hyposensitization treatment.

In the study reported by Hurst (1990), 20 patients between age 3 and 11 years who had a history of otitis media with effusion were offered hyposensitization; those who refused (3 patients) served as controls. In this study, 65 percent of the patients who chose (and complied with) allergy treatment remained disease-free for more than 3 years. During episodes of noncompliance with the allergy treatment, otitis media with effusion returned.

In the Japanese study (Tomonaga, Kurono, and Mogi, 1988), 12 of 41 children with allergic rhinitis who had also had tympanostomy tubes inserted to manage associated otitis media with effusion underwent hyposensitization therapy. In these children, the mean time from extrusion of the tympanostomy tube to recurrence of otitis media with effusion was more than 11 months, compared to a mean time to recurrence in the untreated 29 children of less than 3 months.

Because patients in these studies were older than the target patient for the Guideline, and because the study designs and numbers of patients studied were inadequate, the Panel could not estimate the effectiveness of hyposensitization therapy for otitis media with effusion in children age 1 through 3 years. Furthermore, anaphylactic reactions to hyposensitization have been reported in as many as 6 percent to 11 percent of patients (Ostergaard, Kaad, and Kristensen, 1986; Mosbech, Dirksen, Dreborg, et al., 1990). For some patients, this significant risk of anaphylaxis might well outweigh the possible benefits of hyposensitization for the treatment of otitis media with effusion.

Although the seven reports on the topic of allergy and otitis media with effusion propose plausible theories concerning a connection between allergic rhinitis, eustachian tube physiology, and the development of otitis media, the data available do not fully support or elucidate the nature of the connection. Thus, the Panel could not make any statement regarding the impact of allergy or its treatment on the incidence or prevalence of otitis media with effusion in children.