# Guideline: Surgical Therapies

Surgical intervention is often chosen for the treatment of persistent middle ear effusion. Bilateral myringotomy with insertion of tympanostomy tubes is the most frequently performed procedure. The Panel also examined adenoidectomy, with or without tonsillectomy.

## Myringotomy with Tubes

Recommendation: Myringotomy with or without insertion of tympanostomy tubes should NOT be be performed for initial management of otitis media with effusion in an otherwise healthy child.[Strong recommendation based on evidence that otitis media with effusion resolves spontaneously in most cases and lack of conclusive evidence that a short period of otitis media with effusion has deleterious effects on otherwise healthy children.]

Option: Antibiotic therapy OR bilateral myringotomy with insertion of tympanostomy tubes may be chosen to manage bilateral otitis media with effusion that has lasted a total of 3 months in an otherwise healthy child age 1 through 3 years who has a bilateral hearing deficit (defined as 20 decibels hearing threshold level or worse in the better-hearing ear).[Based on limited scientific evidence and Panel consensus.]

Recommendation: Bilateral myringotomy with insertion of tympanostomy tubes is recommended to manage bilateral otitis media with effusion that has lasted a total of 4 to 6 months in an otherwise healthy child age 1 through 3 years who has bilateral hearing deficit (defined as 20 decibels hearing threshold level or worse in the better-hearing ear).[Moderate recommendation based on limited scientific evidence and strong Panel consensus.]

Myringotomy with insertion of tympanostomy tubes is most often performed under general anesthesia in an ambulatory surgical center. Some physicians perform this procedure in an office setting with sedation and local anesthesia. Statistics from the National Hospital Discharge Survey for 1987 showed a 71 percent decline between 1977 and 1987 in the rate of myringotomy with or without tube insertions performed as an inpatient procedure, from 216,000 to 62,000 procedures (430 to 118 procedures per 100,000 population) (Derkay, 1993). Balancing this trend, however, is the increasing rate at which many procedures, including myringotomy with or without tube insertion, are performed in free-standing surgical centers. The reported rate for myringotomy with or without tubes performed in such a setting in 1986 was nearly 58,000 cases (Henderson, 1986).

Tympanostomy tubes are available in a myriad of designs, most constructed from plastic and/or metal. Variations in tube design reflect attempts to improve ease of tube insertion or removal and to prolong the period of tube retention in the tympanic membrane. Data comparing outcomes for tubes of various designs are sparse, however, and the Panel assumed that there were no notable differences between available tympanostomy tubes.

### Benefits of Tympanostomy Tubes

The principal benefit of myringotomy with insertion of tympanostomy tubes is the restoration of hearing to pre-effusion threshold: removal of the middle ear effusion permits normal vibration of the tympanic membrane and middle ear bones, leading to more efficient transmission of sound across the middle ear to the inner ear. While patent and in place, tympanostomy tubes also permit ventilation of the middle ear tissues, allow for equalization of air pressure across the tympanic membrane, and can prevent further accumulation of fluid or mucus in the middle ear (van Cauwenberge, Cauwe, and Kluyskens, 1979).

There is abundant anecdotal evidence from parents that children are less irritable, sleep better, and communicate better after myringotomy with tympanostomy tube insertion. Parents also reportedly appreciate a return to normal listening levels of volume on the family television set after a child's hearing impairment has been reversed. There are, however, no controlled studies or even case series to document these effects.

### Potential Harms of Tympanostomy Tubes

Morbidity associated with myringotomy and insertion of tympanostomy tubes can include external auditory canal wall laceration, persistent otorrhea, granuloma formation at the myringotomy site, cholesteatoma, and permanent tympanic membrane perforation (Kilby, Richards, and Hart, 1972; Skinner, Lesser, and Richards, 1988; Lildholdt, 1983; Gates, Avery, Prihoda, et al., 1986, 1988; Balkany, Arenberg, and Steenerson, 1986). Structural changes in the tympanic membrane, such as flaccidity, retraction, and/or tympanosclerosis, can also occur, especially in cases of repeated tube insertions (Maw, 1991; Lildholdt, 1983). As high a proportion as 30 percent of children can need to undergo repeat tympanostomy tube insertion within 5 years after the initial surgery (Maw, 1991).

The literature review allowed the Panel to assess the frequency of two specific complications of myringotomy with tympanostomy tube insertion -- tympanosclerosis and postoperative otorrhea. Meta-analysis of data from two studies showed a risk of tympanosclerosis of 51 percent (95 percent confidence interval [43%, 58%]) (Lildholdt, 1983; Maw, 1991). The possible effects of tympanosclerosis on long-term hearing are not known, but the Panel estimated from experience that they would be small. The risk of postoperative otorrhea was calculated by meta-analysis of data from three studies to be 13 percent (95 percent confidence interval [5.5%, 21%]) (Baldwin and Alan 1990; Gates, Avery, Prihoda, et al., 1986, 1988).

Other disadvantages of tympanostomy tubes include the risks associated with the general anesthesia or substantial sedation required for the procedure (Markowitz-Spence, Brodsky, Syed, et al., 1990) and possible limitations on the child's activity while tubes are in place. Many physicians recommend the use of ear plugs to keep water from the ear canal during bathing or swimming because of evidence indicating a higher risk of infection and otorrhea related to water contamination (Arcand, Gauthier, Bilodeau, et al., 1984).

Another problem complicating tube placement is persistent eardrum perforation. Finally, intrusion of the tube into the middle ear cleft instead of normal extrusion into the external ear canal can occur. Because records are not kept of the fate of every tympanostomy tube, the incidence of this complication is not known. It could, however, result in increased risk of further episodes of otitis media, as well as tympanomastoiditis, cholesteatoma, or infection due to the foreign body.

## Adenoidectomy

Recommendation: Adenoidectomy is not recommended for treatment of otitis media with effusion in a child age 1 through 3 years in the absence of specific adenoid pathology.[Based on limited scientific evidence and strong Panel consensus.]

Adenoidectomy has been advocated for the treatment of middle ear effusion as an isolated procedure or in combination with tonsillectomy, or with myringotomy and insertion of tympanostomy tubes. This procedure is most often chosen when nasal obstruction, nasal discharge, snoring, and mouth breathing are present. Maw (1983) noted that, historically, adenoidectomy has been recommended when the eustachian tubes are occluded by hypertrophic adenoidal tissue, compromising middle ear ventilation, or when the adenoids appear to be a focus of ascending eustachian tube infection. Absolute size of adenoid tissue, however, is not related to outcome of surgical management of otitis media with effusion, regardless of the type of surgical procedure (Gates, Avery, Cooper, et al., 1989).

Statistics from the National Hospital Discharge Survey show a decline in the frequency with which adenoidectomy is performed in children younger than age 15 years as an inpatient procedure, from 83,000 procedures in 1978 to 14,000 procedures in 1986 (Derkay, 1993). It is likely that the current frequency of adenoidectomy is somewhat higher than this, however, because of the trend for such procedures to be performed increasingly in outpatient facilities of hospitals or in free-standing ambulatory surgical centers: in 1986, one-fifth of tonsillectomy procedures (with or without adenoidectomy) were performed in such outpatient settings. Concurrent with the change in setting for surgery, indications for adenotonsillectomy changed dramatically: in 1978 obstructive sleep apnea was not listed at all as an indication for this surgery, but in 1987 this diagnosis was the indication for adenotonsillar surgery in one-third of patients of all ages.

### Benefits of Adenoidectomy

For patients whose adenoids obstruct the nasopharynx, adenoidectomy has the immediate benefit of relief of mouth breathing and snoring. Gates, Avery, Cooper, et al. (1989) reported a direct benefit to children 4 years or older both in reducing morbidity from otitis media with effusion and in reducing the number of recurrences. On the basis of these results, adenoidectomy is a clinical option for treatment of bilateral otitis media with effusion lasting 3 months or longer in a child age 4 years or older.

However, in studies of adenoidectomy that included children in the age range targeted for Guideline development, the results for children younger than 4 years could not be separated from results for older children (Maw and Herod, 1986), and the Panel found no literature reporting similar evidence of the efficacy of adenoidectomy in the primary management of otitis media with effusion in very young children. For this reason, the Panel does not recommend adenoidectomy as primary treatment for otitis media with effusion in children younger than 4 years. Although adenoidectomy is not recommended as a treatment for otitis media with effusion in children younger than 4 years, primary indicators for adenoidectomy may in some cases coexist with otitis media with effusion.

### Potential Harms of Adenoidectomy

The morbidity associated with adenoidectomy for children of all ages includes the risks of general anesthesia. A report by the Baltimore Anesthesia Study Committee found that since the mid-1970s anesthesia-related mortality for children younger than 15 years has been less than 1 per 10,000 (Motoyama, 1990). An additional risk is significant postoperative bleeding. No reports of morbidity or mortality from adenoidectomy alone were found. However, a report of case -- fatality rates in Ontario reported a death rate of 0.004 percent (2 deaths among 52,938) from combined tonsillectomy and adenoidectomy operations between 1968 and 1973 (Vayda, Lyons, and Anderson, 1977). Pratt (1970) reported an estimate of similar magnitude-0.006 percent -- from mortality of 6,175,729 tonsillectomy and adenoidectomy procedures performed by 3,617 board-certified U.S. otolaryngologists; deaths were due in almost equal parts to anesthesia factors, cardiac arrest, and hemorrhage. A recent review of 3,488 tonsil and adenoid procedures performed between March 1987 and April 1990 reported a hemorrhage rate of 0.49 percent (Yardley, 1992).

Candidates for adenoidectomy must be selected with care, because when the procedure is performed in a child with a submucous or occult submucous cleft of the palate, the risk is high that adenoidectomy can be followed by velopharyngeal insufficiency and other speech impairments.

The risk of postoperative bleeding, coupled with the lack of consistent evidence that adenoidectomy is effective in treating otitis media with effusion in this age group, led the Panel to decide that adenoidectomy is not an appropriate primary treatment for uncomplicated middle ear effusion in children younger than age 4 years.

## Tonsillectomy

Recommendation: Tonsillectomy should not be performed, either alone or with adenoidectomy, for the treatment of otitis media with effusion in a child of any age.[Strong recommendation based on limited scientific evidence and strong Panel consensus.]

Evidence of the lack of efficacy of tonsillectomy for otitis media with effusion was inferred from a single randomized controlled study comparing adenotonsillectomy to adenoidectomy (Maw and Herod, 1986). Although tonsillectomy alone was not studied, the results from this study show that adding tonsillectomy to adenoidectomy (and, therefore, tonsillectomy alone) is not justified for the treatment of otitis media with effusion. Furthermore, for the older children in this study, adenotonsillectomy offered no significant advantage over simple adenoidectomy for the treatment of otitis media with effusion. The authors noted that the added morbidity of tonsillectomy with adenoidectomy does not at present justify recommendation for removal of the tonsils in addition to adenoidectomy in children with otitis media with effusion; rather, tonsillectomy in these children should be performed for tonsillar pathology per se and not with regard to the status of the middle ear.