# Guideline: Pharmaceutical Therapies

Many pharmaceutical agents have been used to treat otitis media with effusion. The Panel examined evidence for the efficacy in resolving otitis media with effusion, and the adverse effects of, antibiotic agents, adrenocorticosteroid medications, antihistamine and/or decongestant preparations, and combinations of these pharmaceutical agents. The Panel did not examine the efficacy of antibiotics in the prevention of acute otitis media ("prophylaxis") during an episode of otitis media with effusion.

## Antibiotic Therapy

Option: The use of antibiotic agents is one option for the treatment of a child with otitis media with effusion.[Based on limited and inconsistent scientific evidence and Panel consensus.]

Meta-analysis for Guideline development showed a 14 percent increase in the probability that otitis media with effusion would resolve when antibiotic therapy was given versus no treatment (Table 1). When this small improvement in resolution of otitis media with effusion is weighed against the side effects and cost of antibiotic therapy, antibiotic therapy may not be preferable to observation in management of otitis media with effusion in the otherwise healthy young child with no craniofacial or neurologic abnormalities or sensory deficits. To assist in making choices for management of otitis media with effusion, health care providers need to inform parents fully as to the side effects and costs of antibiotic therapy, as well as the benefits and harms of other options for care.

### Efficacy of Antibiotics

Antibiotic medications have been considered for treatment of otitis media with effusion because studies have shown that in 27 to 50 percent of cases, middle ear aspirates from children with otitis media with effusion contain bacteria or provide a medium for bacterial pathogens to grow (Liu, Lang, Lim, et al., 1976; Kokko and Tauno, 1976; Sundberg, 1984; Teele, Healy, and Tally, 1980). However, the existence of bacteria in middle ear aspirates is not proof that the pathogens are causing the effusion or that antibiotic therapy will help resolve the effusion. To explore the role that antibiotic therapy might play in managing otitis media with effusion, the Panel examined the literature on the effectiveness of this therapy in clinical situations.

The literature search identified 18 reports of controlled studies (or reanalyses of controlled study data) and 2 published meta-analyses (Rosenfield and Post, 1992; Williams, Chalmers, Stange, et al., 1993) of antibiotic therapy for otitis media with effusion (Table 4). The two published meta-analyses differed in the studies they included and how the studies were rated, but both concluded that antibiotics have a small but significantly positive effect on resolution of otitis media with effusion. The Panel was also provided an unpublished meta-analysis by Cantekin and McGuire.

Table 4. Studies considered for inclusion in Guideline meta-analysis of antibiotics for otitis media with effusion or included in other meta-analyses

Authors | Treatment groups | No. of patients per group | Outcome measure and time of measurement | No. of patients cured per group
Cantekin, McGuire, and Griffith, 1991 (analysis of data reported by Mandel, Rockette, Bluestone, et al., 1987) | Amoxicillin 40 mg/kg/day + decongestant/antihistamine /Amoxicillin alone /Placebo | 155/155/150 | Otoscopy 4 weeks | 52 / 49 / 25
Cantekin, McGuire, and Griffith, 1991 (analysis of data reported by Mandel, Rockette, Bluestone, et al., 1987) | Same as above | 155 / 154 / 150 | Tympanometry 4 weeks | 26 / 25 / 13
Cantekin, McGuire, and Griffith, 1991 (analysis of data reported by Mandel, Rockette, Bluestone, et al., 1987) | Same as above | 140 / 134 / 131 | Audiometry 4 weeks | 38 / 46 / 43
Chan, Mandel, Rockette, et al., 1988 | Augmentin / Amoxicillin 40 mg/kg/day Amoxicillin each group | 56 / 50 | Algorithm 10 days | 29 / 16
Chan, Mandel, Rockette, et al., 1988 | Same as above | 52 / 45 | Algorithm 4 weeks | 26 / 23
Corwin, Weiner, and Daniels, 1986 | Erythromycin 50 mg/kg/day + Sulfisoxazole 150 mg/kg/day 10 days / No treatment | 66 / 65 | Otoscopy with tympanometric confirmation 1 month | 33 / 22
Daly, Giebink, Batalden, et al., 1991 | Trimethoprim 8 mg/kg/day + Sulfamethoxazole 40 mg/kg/day / Placebo | 21 / 21 | Pneumatic otoscopy and tympanometry 2 weeks | 5 / 2
deCastro, Jaeger, Martin, et al., 1982 | Sulfisoxazole 50 mg/kg/day / Placebo | 15 / 15 | Otoscopy 1 month | 11 / 2
deCastro, Jaeger, Martin, et al., 1982 | Same as above | 15 / 15 | Audiometry 1 month | 10 / 1
deCastro, Jaeger, Martin, et al., 1982 | Same as above | 15 / 15 | Tympanometry 1 month | 5 / 0
Ernstson and Anari, 1985 | Cefaclor 20 mg/kg/day 10 days / No treatment | 46 / 45 | Otoscopy and tympanometry (A and C1) and normal hearing = cured 2-5 weeks | 24 / 5
Giebink, Batalden, Le, et al., 1990 | Trimethoprim-Sulfamethoxazole 40 mg/kg/day / No treatment | 20 / 19 | Algorithm (sensitivity 0.87, specificity 0.74) 4 weeks | 10 / 6
Healy, 1984 | Trimethoprim 8 mg/kg/day + Sulfamethoxazole 40 mg/kg/day / No treatment | 96 / 93 | Positive results on otoscopy and type B or C tympanogram = effusion present 4 weeks | 56 / 6
Mandel, Rockette, Bluestone, et al., 1987 | Amoxicillin 40 mg/kg/day + decongestant/antihistamine / Amoxicillin alone / Placebo | 158 / 160 / 156 | Algorithm 4 weeks | 50 / 46 / 22
Mandel, Rockette, Paradise, et al., 1991 | Erythromycin 50 mg/kg/day + Sulfisoxazole 150 mg/kg/day / Cefaclor 40 mg/kg/day / Amoxicillin 40 mg/kg/day / Placebo | 80 / 77 / 79 / 78 | Algorithm 2 weeks | 17 / 17 / 25 / 11
Mandel, Rockette, Paradise, et al., 1991 | Same as above | 60 / 52 / 54 / 55 | Algorithm 4 weeks | 20 / 26 / 23 / 20
Marks, Mills, and Shaheen, 1981 | Cotrimoxazole / Dimetapp | 25 / 26 | Flat tympanogram to peaked or 20-decibel audiometric improvement = cured 4-6 weeks | 16 / 7
Moller and Dingser, 1990 | Erythromycin 50 mg/kg/day 14 days / Placebo | 69 / 72 | "Air filled" and tympanogram 1 month | 12 / 11
Podoshin, Fradis, Ben-David, et al., 1990 | Amoxicillin 50 mg/kg/day / Placebo | 49 / 37 | Tympanometry 2 months | 20 / 5
Podoshin, Fradis, Ben-David, et al., 1990 | Same as above | 49 / 37 | Audiometry 2 months | 29 / 21
Schloss, Dempsey, Rishikof, et al., 1988 | Erythromycin 50 mg/kg/day + Sulfisoxazole / Placebo Tympanocentesis on all patients | 25/27 | Pneumatic otoscopy, tympanometry, audiometry 2 weeks | 6 / 8
Schwartz and Rodriguez, 1982 | Trimethoprim-Sulfamethoxazole 4 mg/kg/day / Placebo | 33 / 36 | Pneumatic otoscopy and tympanometry 42 days | 29 / 32
Sundberg, Eden, Ernstson, et al., 1981 | Erythromycin 40-60 mg/kg/day / No treatment | 47 / 72 | Otoscopy with some tympanometry, myringotomy, and audiometry 2-5 weeks | 21 / 11
Thomsen, Sederberg-Olsen, Balle, et al., 1989 ^[1]^ | Augmentin 5 mL-7.5 mL three times a day / Placebo | 111 / 110 | Tympanometry (A, C1) = cured 1 month | 69 / 34
Varsano, Volovitz, and Mimouni, 1985 | Sulfisoxazole 250-500 mg two times a day / Placebo | 19 / 16 | Pneumatic otoscopy, 5 weeks | 10 / 8

[1] The data reported in this study were the subject of a letter to the editor (Cantekin EI. Antibiotics for secretory otitis media. Arch Otolaryngol Head Neck Surg 1990 May;16(5):626-8).

The Panel examined antibiotic therapy data particularly carefully because of a conflict in the literature concerning interpretation of data from a study conducted at the Otitis Media Research Center at the University of Pittsburgh. The initial published analysis of these data was challenged by one of the investigators, who published a different interpretation of the data (Cantekin, McGuire, and Griffith, 1991). Because the Panel included individuals who were affiliated with (by having trained or been employed at) the University of Pittsburgh, and because the University of Pittsburgh was the subcontractor for the Guideline literature review, the Panel took several steps to preserve its impartiality in evaluating evidence regarding antibiotic therapy for otitis media with effusion:

- Members of the Panel who were affiliated with the University of Pittsburgh recused themselves from discussions of antibiotic therapy for otitis media with effusion.
- A subcommittee of the Panel was formed to evaluate the conflicting published and unpublished meta-analyses and to provide written recommendations for management of these reports in development of the Guideline (the complete subcommittee report is contained in the Guideline Technical Report).
- All articles originating at the University of Pittsburgh were reviewed independently by an individual not affiliated with the University of Pittsburgh.
- An independent analyst reviewed studies of antibiotic therapy for otitis media with effusion and also reviewed the results of the Panel's analysis of this topic.
- Evaluations of material to be included in this section of the Guideline were performed by individuals not affiliated with the University of Pittsburgh.

The Panel elected to examine all 18 randomized studies and reanalyses of antibiotic therapy for otitis media with effusion, but to concentrate on the 10 studies in which investigators appeared to be effectively blinded to the therapy provided to patients (Table 5, meta-analysis number 8). Antibiotic medications evaluated in these 10 studies included amoxicillin with and without clavulanate potassium, cefaclor, erythromycin with and without sulfisoxazole, sulfisoxazole, and the combination of trimethoprim and sulfamethoxazole.

Table 5. Results of eight meta-analyses of the difference in resolution of otitis media with effusion treated by antibiotic agents and controls as a function of study design

Guideline meta-analysis number | Study types included in meta-analysis | Meta-analysis result ^[1]^ | 95% Confidence interval
1 | Blinded studies with outcomes measured at 10 to 14 days ^[2]^ | 7.6% | -1% to 14%
2 | Blinded studies with outcomes measured at 4 to 6 weeks ^[3]^ | 18.5% | 1.7% to 34.2%
3 | All studies with outcomes measured at 10 to 14 days ^[4]^ | 16.0% | 3.7% to 28%
4 | All studies with outcomes measured at 4 to 6 weeks ^[5]^ | 23.4% | 9.8% to 36.1%
5 | Blinded studies using audiometric outcomes ^[6]^ | 15.4% | -17.8% to 46.4%
6 | Blinded studies using tympanometric outcomes ^[7]^ | 30.8% | 20.1% to 40.7%
7 | Blinded studies using otoscopic/ tympanometric outcomes ^[8]^ | 2.8% | -4.6% to 10.3%
8 | All blinded studies ^[9]^ | 14.0% | 3.6% to 24.2%

[1] Absolute difference in proportion of children experiencing resolution of otitis media with effusion for group treated with antibiotic versus control group.

[2] Schwartz and Rodriguez, 1982; Daly, Giebink, Batalden, et al., 1991; Schloss, Dempsey, Rishikof, et al., 1988; Mandel, Rockette, Paradise, et al., 1991; Moller and Dingser, 1990.

[3] Schwartz and Rodriguez, 1982; Thomsen, Sederberg-Olsen, Balle, et al., 1989; Marks, Mills, and Shaheen, 1981; Mandel, Rockette, Paradise, et al., 1991; deCastro, Jaeger, Martin, et al., 1982; Varsano, Volovitz, and Mimouni, 1985.

[4] Schwartz and Rodriguez, 1982; Daly, Giebink, Batalden, et al., 1991; Ernstson and Anari, 1985; Giebink, Batalden, Le, et al., 1990; Schloss, Dempsey, Rishikof, et al., 1988; Mandel, Rockette, Paradise, et al., 1991; Moller and Dingser, 1990.

[5] Schwartz and Rodriguez, 1982; Thomsen, Sederberg-Olsen, Balle, et al., 1989; Marks, Mills, Shaheen, et al., 1981; Corwin, Weiner, and Daniels, 1986; Giebink, Batalden, Le, et al., 1990; Healy, 1984; Mandel, Rockette, Paradise, et al., 1991; deCastro, Jaeger, Martin, et al., 1982; Varsano, Volovitz, and Mimouni, 1985.

[6] Cantekin, McGuire, and Griffith, 1991; Podoshin, Fradis, Ben-David, et al., 1990; deCastro, Jaeger, Martin, et al., 1982.

[7] Thomsen, Sederberg-Olsen, Balle, et al., 1989; Podoshin, Fradis, Ben-David, et al., 1990; Marks, Mills, and Shaheen, 1981; deCastro, Jaeger, Martin, et al., 1982.

[8] Daly, Giebink, Batalden, et al., 1991; Schloss, Dempsey, Rishikof, et al., 1988; Mandel,Rockette, Paradise, et al., 1991; Moller and Dingser, 1990.

[9] Schwartz and Rodriguez, 1982; Thomsen, Sederberg-Olsen, Balle, et al., 1989; Marks, Mills, and Shaheen, 1981; Mandel, Rockette, Paradise, et al., 1991; Daly, Giebink, Batalden, et al., 1991; Schloss, Dempsey, Rishikof, et al., 1988; Moller and Dingser, 1990; Podoshin, Fradis, Ben-David, et al., 1990; deCastro, Jaeger, Martin, et al., 1982; Varsano, Volovitz, and Mimouni, 1985.

In addition to evaluating a variety of antibiotic agents, these 10 studies used a variety of methods to diagnose the condition and to assess the effectiveness of the medications in treating otitis media with effusion. Methods to diagnose otitis media with effusion in these studies included tympanometry, otoscopy, hearing evaluation, or a combination of these modalities. Investigators in these 10 studies measured outcomes at various times, from a minimum of 10 days to a maximum of 2 months after the start of antibiotic treatment of otitis media with effusion. These differences in study design made meta-analysis of the data challenging.

In developing this Guideline, the Panel performed eight different meta-analyses, each one using a different subset of the available data. The subsets were created based on (1) time until measurement of outcome, (2) type of test used to evaluate outcome, and (3) blinding. The difference was then calculated between the proportion in the antibiotic group and those in the control group that experienced clearance of otitis media with effusion. The results of the meta-analyses, shown in Table 5, are the absolute differences between rate of clearance of otitis media with effusion with antibiotics and rate of clearance without. That is, if otitis media with effusion cleared in 22 percent of cases with antibiotics and in 19 percent without antibiotics, Table 5 shows a 3 percent difference, with a confidence interval for this difference that depends on the sizes of study populations included in the analysis. A negative difference indicates that the rate of clearance of otitis media with effusion was greater in the group of patients not receiving antibiotic therapy.

Panel subgroup evaluation of reports of antibiotic therapy studies originating at the University of Pittsburgh resulted in exclusion of the data from the two reports (Mandel, Rockette, Bluestone, et al., 1987; Cantekin, McGuire, and Griffith, 1991) for determining the effectiveness of antibiotics on otitis media with effusion, due to difficulties with the studies' methodologies. Data from the second report (Cantekin, McGuire, and Griffith, 1991) were ultimately used in meta-analysis 5 (Table 5) because of a lack of data from other sources, but were excluded from the final results reported in meta-analysis 8.

Results of note in Table 5 are the finding of a much greater difference between the antibiotic therapy and control groups when studies used only tympanometry as an outcome measure for otitis media with effusion compared to use of a combination of otoscopy and tympanometry. This difference is unexplained. In turn, the studies using hearing test results as the outcome measure for otitis media with effusion show a much greater difference between antibiotic and control groups than do studies using a combination of otoscopy and tympanometry. A number of factors can account for this difference: (1) not all young children with otitis media with effusion have a clinically significant hearing loss, (2) hearing evaluation results have a greater degree of inaccuracy in young children than in older children and adults, and (3) the meta-analysis was performed on only a few studies.

The above results showing some improvement, albeit small, in clearance of otitis media with effusion with antibiotic treatment do not answer questions about optimal use of this therapy. For example, what is the advantage to the patient of early clearance of otitis media with effusion? Without knowing this advantage, how can parents and health care providers balance this benefit against the potential adverse effects of antibiotic therapy? What is the overall cost-effectiveness of antibiotic therapy, given that no information is available about the degree to which this therapy can decrease the need for more expensive interventions (hearing evaluation and surgery) after 3 to 6 months of otitis media with effusion? One study (Podoshin, Fradis, Ben-David, et al., 1990) that examined outcomes at 2 months showed a 26.5 percent improvement in clearance of otitis media with effusion when antibiotics were used, but longer term studies are needed to determine whether this effect is simply hastening clearance of effusion in children who would experience resolution without treatment, or promoting clearance in children who would not otherwise experience resolution of the effusion.

### Adverse Effects of Antibiotics

Adverse effects of antibiotic therapy range from common to rare and from nuisance to life-threatening. The quality of published evidence linking antibiotic therapy to adverse effects is generally of poor quality, dominated by anecdotes and case reports, mostly in older children and adults. Nevertheless, potentially serious adverse effects -- especially allergic reactions -- do occur with this therapy in young children. The most common adverse effects of antibiotic drug therapy are gastrointestinal, with diarrhea occurring in about 9 percent of children treated with 20-40 mg/kg/day of amoxicillin with clavulanic acid (Table 6). Dermatologic reactions can occur in 3 to 5 percent of cases; severe anaphylactic reactions occur much less frequently; severe hematologic, cardiovascular, central nervous system, endocrine, renal, hepatic, and respiratory adverse effects are more rare still (Table 6). Finally, there is concern that unnecessary use of antibiotics might lead to antimicrobial drug resistance and potentially more serious illness with later episodes of infection.

Table 6. Adverse effects of antibiotic medications most often prescribed for otitis media in children

Antibiotic | Adverse reactions
Amoxicillin/ ampicillin | Diarrhea, usually mild and dose-related (20-30%). Cutaneous allergic reaction (3-5%). Rarely: hematologic, renal, hepatic effects.
Amoxicillin/ clavulanic acid | Diarrhea (9%). Nausea and vomiting (4%). Skin rashes/urticaria (3%). Rarely: hematologic, renal, hepatic effects (mostly in adults).
Cefaclor | Diarrhea (2.5%). Rarely: hematologic, central nervous system, renal, hepatic, dermatologic reactions; serum sickness (more common with cefaclor than with other antibiotics).
Cotrimoxazole | Skin rashes/urticaria (2%). Nausea, vomiting, diarrhea. Rarely: serious dermatologic reaction (less than 0.1%); hematologic, cardiovascular, central nervous system, endocrine, renal, hepatic, respiratory effects. Rare fatalities due to sulfonamides.
Erythromycin | Gastrointestinal effects (dose-related; 2-2.5% for ethylsuccinate or estolate salt administered to children). Subclinical elevations of liver function enzymes (5%). Rarely: serious adverse effects reported for most organ systems.
Sulfisoxazole | Gastrointestinal effects, uncommon (less than 1%). Rarely: serious hematologic (e.g., blood dyscrasias), dermatologic (e.g., Stevens-Johnson syndrome), neurologic, allergic reactions (less than 0.1%).

Source: Computerized Clinical Information System, 30 June 1993 ed. (MICROMEDEX, Inc., Denver, CO).

## Steroid Therapy

Recommendation: Steroid medications are not recommended for treatment of otitis media with effusion in a child of any age.[Based on limited scientific evidence and Panel majority opinion.]The Panel makes no statement regarding the use of steroid medications for conditions other than otitis media with effusion.

The literature on use of adrenocorticosteroid medications to treat otitis media with effusion is growing rapidly. The Panel identified 10 controlled studies and one meta-analysis in which results of this therapy were analyzed. In most of these studies, steroid therapy for otitis media with effusion was of short duration (4 to 10 days), and systemic agents were used. The most frequently used steroid regimen was 1 mg/kg/day prednisone for 2 to 4 days followed by dosage tapering.

### Efficacy of Steroid Agents

A single published meta-analysis of steroids alone or in combination with antibiotics found that both regimens were associated with increased likelihood of resolution of otitis media with effusion (Rosenfeld, Mandel, and Bluestone, 1991). Data on steroid therapy for otitis media with effusion share some characteristics with the data on antibiotic therapy for this condition. Studies report on the use of various steroid agents, and on use of steroids alone or steroid-antibiotic combination therapy with different antibiotic agents. Patient populations and study designs vary, and different techniques are used to measure outcomes.

The Panel performed several hierarchical Bayesian meta-analyses of the literature on steroid therapy for otitis media with effusion. Studies were not weighted for this analysis based on study design, as they had been in the previously published meta-analysis.

#### Steroid Therapy Compared to Placebo

Data from three reports of studies comparing steroid medications to placebo for treatment of otitis media with effusion were combined (Niederman, Walter-Buchholtz, and Jabalay, 1988; Macknin and Jones, 1985; Giebink, Batalden, Le, et al., 1990). Data were analyzed at two different times (2 weeks and 4 to 6 weeks) after treatment. The difference in mean improvement of otitis media with effusion 2 weeks after treatment was 18.4 percent (not statistically significant; the 95 percent confidence interval was [-3.4%, 38.6%]) in favor of steroid therapy. By 4 to 6 weeks after treatment the difference in mean improvement was 4.5 percent (not statistically significant; the 95 percent confidence interval was [-11.7%, 20.6%]). The mean differences in favor of steroid therapy indicate a trend for steroid therapy alone to promote improvement of otitis media with effusion. However, the small sample sizes in these studies, and the fact that confidence intervals for the meta-analysis include zero, indicate that this therapy provides no statistically significant benefit over placebo. In addition, the decreasing trend in improvement (from 18.4 percent to 4.5 percent) with time indicates that any benefits of steroid therapy alone are short-lived; any later improvements would be difficult to distinguish from improvements due to spontaneous resolution of otitis media with effusion.

#### Antibiotic-Steroid Therapy Compared to Antibiotics Alone

Five studies were examined for meta-analysis of antibiotic-steroid therapy compared to antibiotic therapy alone as treatment for otitis media with effusion. The time to measurement of results varied from 1 week to 2 months after treatment, and various antibiotic agents were used in the studies.

Analysis of four of these studies (Schwartz, Puglese, and Schwartz, 1980; Berman, Grose, Nuss, et al., 1990; Podoshin, Fradis, Ben-David, et al., 1990; Lambert, 1986), one of which (Podoshin, Fradis, Ben-David, et al., 1990) had not been available when the earlier (Rosenfeld, Mandel, and Bluestone, 1991) meta-analysis was performed, showed a difference in mean improvement for antibiotic-steroid therapy compared to antibiotic therapy alone of 25.1 percent (not statistically significant; the 95 percent confidence interval was [-1.3%, 49.9%]). The fifth study (Persico, Podoshin, and Fradis, 1987) was excluded from this Guideline meta-analysis because, although the study reported on a large sample of patients, the patients were not assigned randomly to study groups.

Results of the meta-analysis of existing studies closely approach but do not reach statistical significance, but they indicate a rather high probability that the antibiotic and steroid combination is more effective than antibiotic alone. Additional or larger studies will be needed to prove whether this difference exists.

#### Antibiotic-Steroid Therapy Compared to Placebo

Only three studies were found that examined the effects of antibiotic-steroid therapy compared to placebo (Berman, Grose, and Zerbe, 1987; Podoshin, Fradis, Ben-David, et al., 1990; Lildholdt and Kortholm, 1982), and in one of these studies beclamethasone nasal spray was used rather than a systemic steroid agent (Lildholdt and Kortholm, 1982). Meta-analysis of the results, measured in the studies between 1 and 2 months after treatment of otitis media with effusion, showed a mean difference in improvement of otitis media with effusion due to antibiotic-steroid therapy of 21.4 percent (not statistically significant; the 95 percent confidence interval was [-1.4%, 42.6%]).

When the results of the three meta-analyses (efficacy of steroid versus placebo; antibiotic-steroid versus antibiotic, and antibiotic-steroid versus placebo) were compared, a paradox arose:

- Antibiotic-steroid combination therapy led to more improvement in otitis media with effusion than did antibiotic therapy alone when both were compared to placebo.
- However, steroid therapy alone led to less improvement in otitis media with effusion compared to placebo than did antibiotic-steroid therapy compared to antibiotic therapy alone.
- Furthermore, improvement with antibiotic-steroid therapy versus antibiotic alone was significantly better than improvement with antibiotic-steroid therapy versus placebo.
- Similarly, antibiotic alone resulted in less improvement than placebo in studies comparing antibiotic-steroid therapy to antibiotic alone or to placebo.

These results imply that antibiotic therapy slows the rate of resolution of otitis media with effusion -- an implication that is not compatible with results of controlled studies of antibiotics versus placebo.

This paradox can be explained partially by differences among studies in times at which outcomes were measured. All but one of the studies of antibiotic-steroid therapy versus antibiotic therapy alone examined resolution of otitis media with effusion 3 weeks or less after treatment. Studies of antibiotic-steroid therapy versus placebo, however, all recorded outcomes 1 to 2 months after therapy. As with steroid therapy alone, when steroid is combined with an antibiotic agent, an early enhancement of outcome can result that is lost with time; by 1 to 2 months after treatment, small effects of steroid therapy can be difficult to distinguish from spontaneous resolution of otitis media with effusion. Variations in time to recorded outcome cannot totally explain differences in study results; there appear to have been considerable variations in patient populations for these studies, either according to site or selection. In summary, additional data are needed before a recommendation can be made for the utilization of steroids to treat otitis media with effusion.

### Adverse Effects of Steroids

Steroid medications can have adverse effects, but, as with antibiotic medications, the quality of published evidence is poor, dominated by reports of cases, almost all older children and adults. The Panel identified agitation, behavior changes, sleeplessness, increase in appetite, and weight gain as possibly common in children who have undergone short-term steroid therapy. Serious or rare adverse effects of steroid therapy include gastrointestinal disorders, angina, Cushing's disease, and (by anecdotal report) disseminated varicella in young children who had been exposed to varicella in the month before administration of steroid medication. The small sample sizes in controlled studies and the notable adverse effects of steroid medications led the Panel to recommend that use of steroid agents is still investigational for treatment of otitis media with effusion. If used to treat otitis media with effusion, steroid drugs should only be administered to children who have had varicella.

## Antihistamine/Decongestant Therapy

Recommendation: Antihistamine and/or decongestant agents are not recommended for treatment of otitis media with effusion.[Strong recommendation based on evidence that can be generalized to a child of any age.]The Panel makes no statement regarding the use of antihistamine and/or decongestant medications for conditions other than otitis media with effusion.

Antihistamine and decongestant medications have been used separately or together for decades to treat otitis media with effusion. The Panel found, however, that the four randomized controlled studies of this therapy failed to show a statistically significant effect of these medications in resolving otitis media with effusion.

The first reported study of antihistamine/decongestant therapy for otitis media with effusion was a three-armed study of decongestant alone (phenylpropanolamine), decongestant with antihistamine (phenylpropanolamine with brompheniramine maleate), and placebo. The results showed weak negative trends for both active treatments against placebo, not reaching statistical significance (Haugeto, Schroeder, and Mair, 1981).

The second published report of antihistamine/decongestant therapy for otitis media with effusion was a double-blinded study of the combination chlorpheniramine maleate and pseudoephedrine hydrochloride in 553 children. The medication showed a very weak (p=0.74) negative tendency to resolve otitis media with effusion in children with unilateral effusion and a very weak (p=0.67) positive tendency to resolve effusion in those with bilateral effusion (Cantekin, Mandel, Bluestone, et al., 1983).

The third study in which antihistamine and decongestant agents were evaluated for otitis media with effusion was a double-blinded study in which antihistamine (chlorpheniramine) alone, decongestant (pseudoephedrine) alone, or placebo was administered. The decongestant showed a very weak positive trend and the antihistamine showed a very weak negative trend toward more effective resolution of otitis media with effusion compared to placebo or the other active agent. The results were not statistically significant, however (Dusdieker, Smith, Booth, et al., 1985).

The last trial the Panel examined in this category was a three-arm, double-blinded study of antibiotic (amoxicillin), antibiotic with antihistamine/decongestant (amoxicillin with chlorpheniramine maleate and pseudoephedrine hydrochloride), and placebo. In this study, addition of antihistamine/decongestant medications to antibiotic therapy showed a weak positive trend for improvement in otitis media with effusion, but the added effect of antihistamine/decongestant therapy was not statistically significant (Mandel, Rockette, Bluestone, et al., 1987).

Meta-analysis of the results reported in these four studies was performed for this Guideline by the hierarchical Bayes method. This meta-analysis showed that the antihistamine/decongestant combination had no effect on resolution of otitis media with effusion (mean, -0.009; 95 percent confidence interval [-0.036, 0.054]).

Antihistamine/decongestant medications can also have adverse effects, including insomnia, drowsiness, behavior changes, changes in blood pressure, and seizures.