# Guideline: Control of Environmental Risk Factors

The Panel conducted a literature review of environmental risk factors for otitis media with effusion, with the goal of identifying preventive interventions for this condition. Reports were found of research into the association of infant feeding practices, passive smoking, and child-care facility placement with the occurrence of otitis media with effusion, with or without other types of otitis media. None of the studies reported, however, was designed to test the direction or strength of the linkage between these environmental factors and the incidence or natural history of otitis media with effusion, and the articles found were not subjected to the same level of scrutiny by the entire Panel that was accorded articles reporting diagnostic and treatment interventions. The remainder of this chapter describes the findings of the literature review. These findings did not provide information regarding whether intervening to decrease environmental risk factors would make a clinically important difference in the care of otherwise healthy young children with otitis media with effusion.

Option: Parents should be encouraged to control environmental risk factors.[Option based on limited scientific evidence and strong Panel consensus.]

## Infant Feeding Practices

The Panel reviewed literature linking early infant feeding practices to later otitis media, even though the target patient for Guideline development was past the age when a change in infant feeding practices would have much effect in preventing middle ear effusion.

Some studies of breast-feeding versus bottle-feeding showed a several-fold increase in otitis media in bottle-fed compared to breast-fed infants (Saarinen, 1982; Cunningham, 1979; Chandra, 1979; Duncan, Ey, Holberg, et al., 1993; Teele, Klein, and Rosner, 1989; Alho, Koivu, Hartikainen-Sorri, et al., 1990), suggesting that breast-feeding may provide some protection against otitis media. In addition, Eskimo and Inuit studies point to a link between bottle-feeding and an increased incidence of chronic otitis media (Timmermans and Gerson, 1980).

The available literature on infant feeding practices and otitis media is descriptive and focuses on acute otitis media, not on otitis media with effusion. Thus, although studies suggest that bottle-fed infants are two or three times more likely to have episodes of acute otitis media during the first year of life, the proportion who develop otitis media with effusion as a consequence is unknown. Furthermore, the direction of the linkage cannot be determined from available research. For example, perhaps infants with acute otitis media are weaned to the bottle earlier, giving the appearance that bottle-feeding is correlated with acute otitis media when in fact the acute otitis media "caused" bottle-feeding. Finally, the linkage is not firm: several studies have failed to find an association between feeding practices and otitis media (Tainio, Savilahti, Salmenpera, et al., 1988; Paine and Coble, 1982).

Some experts believe that propping a feeding bottle is a practice that may promote the occurrence of otitis media with effusion. The hypothesis is that when a bottle is propped in place, fluid is forced under pressure into the oral cavity, leading to reflux into the middle ear (Bluestone and Klein, 1988). The Panel could locate no research related to bottle propping and otitis media with effusion.

In summary, available research linking infant feeding practices to otitis media with effusion is provocative, but inconclusive. If a causal link is eventually demonstrated, better parent education about infant feeding practices might lead to fewer episodes of otitis media with effusion in later years. By the time a child reaches the age considered in this Guideline, however, the issue is only of historical interest.

## Passive Smoking

Evidence that passive smoking may be related to otitis media with effusion has been reported only during the past decade and is limited. Kraemer, Richardson, Weiss, et al. (1983) documented a relative risk of 2.8 for children in households with two or more smokers in an early case-control study. Two other independent early studies documented odds ratios of 1.6 for parental smoking and abnormal tympanometry results or for the risk of surgery for glue ear (Iverson, Birch, Lundqvist, et al., 1985; Black, 1985). In a case-control study, 57 percent of children with otitis media with effusion (cases) had at least one parent who smoked, compared with 39 percent of children without otitis media with effusion (controls) (Hinton, 1989). A more recent case-control study of similar design, however, failed to find the same association (Rowe-Jones and Brockbank, 1992). In a followup study of children with severe chronic otitis media with effusion (glue ear), parental smoking delayed the time to resolution regardless of treatment chosen (Maw and Bawden, 1993).

Two studies found a correlation between higher levels of serum cotinine (a marker for nicotine) and otitis media with effusion. In a randomly chosen sample of Edinburgh primary school children, a direct correlation was found between serum cotinine levels and abnormal tympanograms (Strachan, Jarvis, and Feyerabend, 1989). Another study found a 38 percent higher rate of new episodes of otitis media during the first 3 years of life in children with high levels compared with children with low or undetectable levels of serum cotinine (Etzel, Pattishall, Haley, et al., 1992); the authors estimated that approximately 8 percent of cases of otitis media with effusion and 18 percent of the days with otitis media with effusion may be attributable to passive smoking.

Overall, studies have shown a moderate association between passive smoking and otitis media with effusion. Although proof is lacking that cessation of passive smoking will help prevent otitis media with effusion, the association of passive smoking with otitis media with effusion is consistent across a variety of study designs and is biologically plausible. Thus, the possibility that freedom from passive smoking will decrease a child's risk for and time with otitis media with effusion should be added to the many other reasons for parents and child-care providers to stop smoking.

## Child Care

Descriptive research conducted during the past 15 years consistently shows a relationship between otitis media with effusion and child care in group facilities (child-care facilities). This relationship has been observed in the context of research demonstrating an association between many common childhood infections and child-care facility attendance.

One of the earliest population-based studies found a three- to fourfold increase in the prevalence of secretory otitis media in children attending child-care facilities, regardless of season of year (Fiellau-Nikolajsen, 1979). An early Danish study that explored the relationship between otitis media with effusion and a number of factors in the child's history found abnormal tympanograms in 76 percent of children cared for in public child-care facilities versus 69 percent of children cared for at home, a difference that was not statistically significant and not adjusted for other factors (Sorenson, Holm-Jensen, and Tos, 1981). A British case-control study found a relative risk of between 1.47 and 2.00, depending on the control group selected, for otitis media with effusion in young children, adjusted for household smoking, parental working, family history, residence, and type of heating system (Black, 1985). A cohort study in Denmark of children cared for at home or in child-care facilities found that the common cold was followed by secretory otitis media in 56 percent of 1-year-old children cared for at home versus 83 percent cared for in child-care facilities, but that the rate was 20 percent in both groups by the time children attained the age of 5 years (Birch and Elbrond, 1987).

A study of 386 children in Minnesota with recurrent acute otitis media and otitis media with effusion at entry found an odds ratio of 1.2 for child-care facility placement and otitis media with effusion after adjustment for age, age at first episode of otitis, season of birth and enrollment, and antibiotic prophylaxis (Daly, Giebink, Le, et al., 1988). Two population-based European studies found odds ratios of 1.7 and 1.8 for otitis media with effusion in children attending child-care facilities, but variably adjusted for confounding factors (Zielhuis, Heuvelmans-Heinen, Rach, et al., 1989; Alho, Koivu, Hartikainen-Sorri, et al., 1990). A similarly designed Swedish cohort study of 1,306 children found a slightly higher relative risk of 2.6 (Rasmussen, 1993).

All of the studies surveyed suffered from one or more design flaws. For example, many studies were retrospective, and some of the cohort studies were conducted on children already known to be at high risk of otitis media with effusion. More importantly, the cause of otitis media with effusion is multifactorial, and none of the studies adequately adjusted for all known confounding factors.

Despite their shortcomings, these studies point consistently to an association between child-care facility attendance and otitis media with effusion. The relative risks are modest (less than 2.0), but potentially very important given the size of the population base. Furthermore, data recently reported from a cohort study of 2,512 newborns followed for 2 years suggest that removing a child from the group child-care environment might lead to a lower incidence of acute otitis media (Alho, Kilkku, Oja, et al., 1993). More research is needed, however, to establish whether removing the child from a group child-care facility prevents otitis media with effusion, or speeds its resolution.