# Guideline: Diagnosis and Hearing Evaluation

In the diagnosis of any health problem, the first step is to obtain a thorough medical history. The history for a child suspected of otitis media with effusion should include date of onset of signs or symptoms of middle ear inflammation, previous treatments (nonprescription as well as prescribed medications and treatments), and the degree of compliance with treatment regimens. The history might also include assessment of environmental risk factors shown by epidemiologic studies to be related to otitis media with effusion, especially infant feeding practices, passive smoking, and child-care facility placement (see Chapter 5).

The general physical examination of a child in whom otitis media with effusion is suspected should include an assessment of growth and development and whether an infectious disease is present. Examination of the head and neck is also crucial in identifying conditions associated with or predisposing to otitis media with effusion, such as nasal obstruction or craniofacial anomalies affecting the middle ear (cleft palate, for example) (Bluestone and Klein, 1990).

Otitis media with effusion can be diagnosed definitively only when the presence of fluid in the middle ear is confirmed. In the best-designed clinical research studies of diagnostic methods for otitis media with effusion, the diagnostic method to be evaluated (such as pneumatic otoscopy or tympanometry) is implemented and followed immediately by myringotomy (performed in the context of an indicated surgical procedure, such as the insertion of ventilation tubes) to document the effusion. Without myringotomy, diagnostic methods in common use provide only indirect evidence for the presence of fluid.

In conducting the literature review for diagnostic tests, the Panel searched for studies in which the selection criteria, patient population, and diagnostic methods were clearly described; patients' medical histories were consistent with otitis media with effusion as defined by the Panel; and the presence of effusion was validated by performance of myringotomy by a surgeon who was blinded to results from the initial diagnostic test. An important methodological issue is that the true sensitivity, specificity, and negative predictive value of diagnostic tests for the presence of middle ear effusion are not known, because myringotomy has not been performed in a matched group of children in whom otitis media with effusion is not suspected. The numbers of subjects with and without effusion who have a negative initial test must be known in order to calculate a test's sensitivity, specificity, and negative predictive value (Table 3).

Table 3. Definitions of sensitivity, specificity, positive predictive value, and negative predictive value of tests to diagnose middle ear effusion, validated by findings at myringotomy

| Findings at myringotomy
Diagnostic test result | Percentage with effusion | Percentage with no effusion
Abnormal test result | a | b
Normal test result | c | d

a = number of true positive test results

b = number of false positive test results

c = number of false negative test results

d = number of true negative test results

Sensitivity = a/(a+c)

Sensitivity = d/(b+d)

Positive predictive value = a/(a+b)

Negative predictive value = d/(c+d)

Because ethical considerations preclude a study involving myringotomy in healthy children with apparently normal ears, and limited data are available that correlate a negative screening test with effusion when otitis media with effusion is suspected on other grounds, the only valid test measure available from published research is the predictive value of a positive test: the likelihood that an effusion is present if the initial diagnostic test is positive. On this basis, the Panel searched for literature describing the relationship of otoscopy, pneumatic otoscopy, tympanometry, acoustic reflectometry, tuning fork tests, and hearing evaluation with middle ear effusion as determined by myringotomy.

## Otoscopy and Pneumatic Otoscopy

Recommendation: The diagnostic evaluation of suspected otitis media with effusion should include pneumatic otoscopy. Otoscopy alone (without the use of the pneumatic otoscope to test tympanic membrane mobility) is not recommended.[Strong recommendation based on limited scientific evidence and strong Panel consensus.]

The history and physical examination provide vital clues to the presence of otitis media with effusion. However, confirming the diagnosis requires establishing the presence of a middle ear effusion. The principles and usefulness of pneumatic otoscopy for detecting effusion were first reported by Siegle more than a century ago and popularized by Politzer (1909). Pneumatic otoscopy is a two-step procedure. In the first step, the clinician inspects the ear canal and eardrum visually, using a light source and magnification (otoscopy). In the second step, the clinician creates a seal in the ear canal and applies very slight positive and then negative pressure while watching the tympanic membrane to evaluate its mobility (pneumatic otoscopy).

On otoscopy, the clinician assesses tympanic membrane color, translucency, and resting position (retracted, neutral). The normal tympanic membrane is translucent, with a ground-glass appearance. Usually pearly grey, even a healthy tympanic membrane turns red when the patient cries. Although otoscopes are ubiquitous in clinical settings, few data are available correlating otoscopic findings with the presence of middle ear effusion, and few studies have provided any information about the criteria that suggest effusion. In one study, Finnish researchers sought to correlate tympanic membrane appearance with effusion in children with acute otitis media and otitis media with effusion; the predictive values of visible eardrum characteristics ranged widely (Karma, Penttila, Sipila, et al., 1989).

The pneumatic otoscope, which allows the examiner to observe movement of the tympanic membrane directly, has been widely credited as an advance over otoscopy alone, because pneumatic otoscopy can suggest the presence of effusion even when the appearance of the eardrum gives no indication of middle ear pathology. For this test, crisp movement of the tympanic membrane with slight application of pressure is normal. Thickening of the eardrum causes it to be less mobile. If the tympanic membrane does not move perceptibly with applications of slight positive or negative pressure, a middle ear effusion is highly likely. The examiner should note, however, that almost any eardrum will move if enough pressure is applied. Sometimes application of pressure will reveal an air-fluid level behind the tympanic membrane, and this is diagnostic of a middle ear effusion (Bluestone and Klein, 1990).

When employed under rigorously controlled conditions (i.e., when results of the procedure performed by a clinician who was validated using a prescribed protocol are compared with results of myringotomy performed by another clinician immediately after the procedure), pneumatic otoscopy was found in one study to have a sensitivity of 85 to 90 percent and specificity of 70 to 79 percent (Kaleida and Stool, 1992). In this study, the clinical indications for myringotomy were not clearly described; however, the prevalence of middle ear effusion in the study population must be assumed to be high.

In another study comparing findings at pneumatic otoscopy and at myringotomy, positive and negative predictive values of pneumatic otoscopy for middle ear effusion were found to be 91 percent and 84 percent, respectively (Toner and Mains, 1990). Because, as just discussed, the expectation of middle ear effusion must be very high in a study population to justify myringotomy in every child, the prevalence of otitis media with effusion was probably higher than would be found in a typical clinical setting. Thus, in a typical clinical setting, the positive predictive value of pneumatic otoscopy would be lower and the negative predictive value higher than in the research setting. Another factor that would tend to decrease the positive predictive value and increase the negative predictive value of this test in clinical settings is the lack of calibration of test results against findings at myringotomy.

## Tympanometry

Option: Tympanometry may be used as a confirmatory test for otitis media with effusion.[Option based on limited scientific evidence and expert opinion.]

Many studies have been conducted to identify correlations between tympanometric findings and the presence of middle ear effusion at myringotomy. Problems have arisen with application of findings to clinical practice, however, because of variations in the way tympanograms have been categorized and the absence of data that would allow calculation of the true sensitivity, specificity, and negative predictive values in typical practice populations.

Early research into the association of tympanometric curves with conditions in the middle ear classified tympanometry results into four or more categories (Jerger, 1970; Bluestone, Beery, and Paradise, 1973; Paradise, Smith, and Bluestone, 1976; Shurin, Pelton, and Finkelstein, 1977; Cantekin, Beery, and Bluestone, 1977). Later research classified tympanogram curves into three categories: Type A (peaked, normal middle ear pressure), Type B (flat), and Type C (peaked, negative middle ear pressure, sometimes further divided into two types according to degree of negative pressure) (Jerger, Anthony, Jerger, et al., 1974; Tos, Poulsen, and Borch, 1978; Fiellau-Nikolajsen, 1980 a, b).

The most recent research has further collapsed the three types into two clinically useful categories: normal (Types A, C, and D, peaked) and abnormal (Type B, flat) (Toner and Mains, 1990; Dempster and MacKenzie, 1991; Babonis, Weir, and Kelly, 1991). In the following discussion, the simpler two-category classification is used. Tables in the original reports that used more complex classification schemes were collapsed into the simpler system to fit diagnostic information from the early studies into a format consistent with current practice.

The positive predictive value for middle ear effusion of a flat (Type B) tympanogram (i.e., the likelihood that an effusion is present if the tympanogram is abnormal) has been found to be between 49 and 99 percent (Fiellau-Nikolajsen, 1980 a, b; Orchik, Morff, and Dunn, 1980; Ben-David, Podoshin, and Fradis, 1981; Babonis, Weir, and Kelly, 1991). In a few studies, tympanometry was performed in children who were scheduled for myringotomy indicated for reasons other than tympanometric findings. A negative predictive value for tympanometry can be estimated from the few patients in these studies who had normal tympanogram results and who underwent myringotomy. In this highly selected population, the negative predictive value of a normal tympanogram (i.e., the likelihood that no effusion is present when the tympanogram is normal) was estimated to be between 64 and 93 percent (Fiellau-Nikolajsen, 1980 a, b; Orchik, Morff, and Dunn, 1980; Ben-David, Podoshin, and Fradis, 1981).

Since tympanometry became clinically available, clinicians have sought to use this diagnostic tool as a screening test for otitis media with effusion (Paradise, Smith, and Bluestone, 1976). Indeed, it has been used as a screening test (without myringotomy for confirmation) by many researchers in the United States and Europe. Longitudinal cohort studies of children followed with tympanometry have provided some of the best data available regarding the natural history of otitis media with effusion. In particular, such studies have shown that otitis media with effusion resolves without treatment in most cases (Tos, Poulsen, and Borch, 1978; Fiellau-Nikolajsen, 1980 a, b; Roland, Finitzo, Friel-Patti, et al., 1989).

Although several articles reviewed by the Panel mention in passing the possibility of using tympanometry as a surrogate for hearing evaluation, the Panel did not find direct evidence in support of this strategy. The clinical utility of tympanometry is limited to measuring the mobility of the tympanic membrane and ossicles and providing an estimate of middle ear pressure. As such, it is neither an appropriate nor a reliable predictor of hearing impairment, except in the most nonspecific sense as a risk marker for the hearing impairment associated with middle ear pathology. Indeed, the positive predictive value for hearing loss of an abnormal tympanogram has been reported to be as low as 49 percent (Dempster and MacKenzie, 1991). Clearly, with a positive predictive value for hearing loss of only 49 percent, tympanometry cannot be used in place of hearing evaluation- half the patients with abnormal tympanometric results could have normal hearing, and theoretically, half with normal results could have abnormal hearing. The negative predictive value, however, is 98 percent (Dempster and MacKenzie, 1991), reflecting the lower prevalence of sensorineural hearing impairment. That is, few children with normal tympanograms have hearing impairment, although those with pure sensorineural pathology and no middle ear involvement do have normal tympanograms. The American Academy of Pediatrics Committee on School Health (1987) specifically recommends against use of tympanometry as the primary screening test for hearing impairment.

## Combination of Tympanometry and Pneumatic Otoscopy

Although pneumatic otoscopy and tympanometry essentially measure the same thing -- tympanic membrane mobility -- the strengths of one test can offset the weaknesses of the other. For example, tympanometry gives a quantitative measure of tympanic membrane mobility, whereas pneumatic otoscopy gives only a qualitative measure of this variable. In addition, a false-positive tympanometry result (abnormal tympanogram in the absence of effusion) can be caused by impacted cerumen, a foreign body, tympanic membrane perforation, medial canal stenosis, or improper placement of the instrument tip on the canal wall; performing pneumatic otoscopy before or after tympanometry provides information about ear anatomy and tympanic membrane mobility critical to interpretation of tympanometry results. Accordingly, the Panel recommends pneumatic otoscopy as the primary diagnostic test. Tympanometry may be used as a confirmatory test.

Because of the complementary nature of these two tests, researchers have constructed algorithms for the diagnosis of otitis media with effusion based on combined tympanometric and pneumatic otoscopic findings. Algorithms in widest use include those proposed by Cantekin (1983) and updated by Brostoff and Cantekin (1988). The Panel did not find direct evidence linking the outcome of these algorithms to the presence or absence of middle ear effusion. Le, Daly, Lindgren, et al. (1992) proposed an algorithm in which results of diagnostic testing are validated against findings at myringotomy. None of the research algorithms combining pneumatic otoscopy and tympanometry has been tested for usefulness in clinical practice.

## Acoustic Reflectometry

No Recommendation: No recommendation is made regarding the use of acoustic reflectometry as a screening or diagnostic test for otitis media with effusion.

Acoustic reflectometry is a relatively new technique in which a tone sweep is presented to the patient's ear canal and the reflected sound pressure is recorded in decibels. The initial report of this technique stated that in one population of children, in most of whom middle ear disease had been diagnosed by some other method, acoustic reflectometry had high (86 percent) sensitivity and high (76 percent) specificity for otitis media with effusion when correlated with findings at myringotomy (Teele and Teele, 1984). Even higher sensitivity (98.7 percent) and specificity (94.5 percent) were obtained when reflectivity and angle were optimized and tympanometry was used as the reference standard (Combs, 1991). Other studies have not yielded consistent results, with sensitivity of this test ranging from 80 to 87 percent and specificity ranging from only 54 to 70 percent (Lampe, Weir, Spier, et al., 1985; Avery, Gates, and Prihoda, 1986; Babonis, Weir, and Kelly, 1991). One of these studies examined the receiver-operator characteristic of acoustic reflectometry and found no acceptable breakpoint dividing a high probability of effusion from a low probability of effusion; this study did, however, suggest that the absolute value can be less important than documenting a change in a single individual (Avery, Gates, and Prihoda, 1986).

The Panel judged the evidence in support of acoustic reflectometry to be insufficient to make a recommendation regarding use of this test in screening for or diagnosis of otitis media with effusion.

## Tuning Fork Tests

No Recommendation: No recommendation is made regarding the use of tuning fork tests in screening for or diagnosis of otitis media with effusion, except to note that they are inappropriate in the youngest children.

The Panel recognized that many experts use tuning fork tests to evaluate hearing and as an indirect means to diagnose otitis media with effusion by assessing conductive hearing loss. However, the Panel found no reports of studies that used other tests as standards against which to judge the sensitivity, specificity, and predictive value of tuning fork tests to identify otitis media with effusion in children. Furthermore, tuning fork tests are not reliable or even appropriate for use in the youngest children covered by this Guideline. A number of methods to test directly for the presence of a middle ear effusion, including pneumatic otoscopy and tympanometry, have been discussed, and better methods are available to assess hearing (see next section).

## Hearing Evaluation

Option: Hearing evaluation may be performed before otitis media with effusion has been present for a total of 3 months.[Option based on insufficient evidence.]

Recommendation: Hearing evaluation is recommended for a child who has had bilateral otitis media with effusion for a total of 3 months.[Recommendation based on limited scientific evidence and expert opinion.]

A change in hearing threshold is both a clinical outcome and a possible indicator of the presence of otitis media with effusion. Tests that may be used to evaluate hearing (listed in approximate order from those requiring greatest language and communication skills from the patient to those requiring the least skills) include: (1) pure tone threshold audiometry measuring both air and bone conduction, (2) speech reception threshold audiometry, (3) speech awareness threshold audiometry, (4) behavioral observation audiometry, and (5) auditory brainstem response recording and evaluation.

Children who fail hearing screening tests are usually referred to a physician, but the Panel found no direct evidence to estimate the proportion of these children who have otitis media with effusion. The corollary linkage between otitis media with effusion and hearing is better understood: several studies have documented hearing impairment in children with otitis media with effusion diagnosed by tympanometry and pneumatic otoscopy (Fria, Cantekin, and Eichler 1985; Friel-Patti and Finitzo, 1990; Dempster and MacKenzie, 1991). Otitis media with effusion is not always associated with hearing impairment, however. For example, one well-designed study of language learning and hearing in very young children with otitis media with effusion found a correlation of only 0.44 between days with effusion and average hearing over a 12-month period (Friel-Patti and Finitzo, 1990). Days of effusion accounted for less than 20 percent of the observed variation in hearing in this study.

The Panel recognizes that none of the hearing tests found to be effective (with the exception of pure-tone threshold audiometry, which is appropriate only for older children) is routinely available in many primary care settings, especially in rural areas. Furthermore, the Panel recognizes that there are difficulties with the validity, availability, and cost of hearing testing in the youngest children. Nevertheless, for otherwise healthy children age 1 through 3 years, the Panel recommends hearing evaluation after otitis media with effusion has been present bilaterally for 3 months, because of the strong belief that the placement of tympanostomy tubes is not indicated when otitis media with effusion is unaccompanied by bilateral hearing impairment (defined as 20 decibels hearing threshold level or worse in both ears).

Methods used to determine the child's hearing acuity will vary depending on resources available in the community and the child's willingness and ability to participate in testing. Optimally, air- and bone-conduction thresholds can be established for 500, 1,000, 2,000, and 4,000 Hz, and an air-conduction pure tone average can be calculated. This result can then be verified by obtaining a measure of speech sensitivity. Determinations of speech reception threshold and speech awareness threshold are less precise but still acceptable measures of hearing acuity. In the event that facilities or resources are not readily available or the child is unable to cooperate in such testing, the health care provider should use his/her best judgment as to the adequacy of the child's hearing. In these cases, the health care provider should take into consideration whether the child is achieving the appropriate developmental milestones for communication skills.