# Guideline: Clinical Outcomes Addressed

The development of recommendations for otitis media with effusion is complicated by a lack of sufficient data about the most important outcomes. Otitis media with effusion is very common in young children; however, most effusions (about 60 percent in one large study; Zielhuis, Straatman, Rach, et al., 1990) spontaneously resolve by 3 months. The major short-term outcomes (weeks to months) that have been identified include discomfort and behavior changes; the long-term outcomes (months to years) of concern are the impact of hearing loss on speech and language development, with possible deficits in language, speech, learning, and behavior. For children who undergo myringotomy with insertion of tympanostomy tubes, adverse long-term outcomes may include changes in the tympanic membrane, such as tympanosclerosis and persistent perforation. The Panel identified cholesteatoma, mastoiditis, and inner ear damage as other possible long-term effects of otitis media with effusion, but these problems apparently occur so rarely that they were not reported in the controlled studies evaluated by the Panel.

The Panel also found inadequate evidence in the literature regarding short- and long-term effects of treatment on speech, language, discomfort, and behavior to permit direct estimation of treatment effects on these outcomes. Instead, studies reported in the literature focused on an intermediate outcome of treatment, clearance of the middle ear effusion.

## Short-Term Outcomes

Table 1 shows the relative benefits and harms of the treatment interventions the Panel examined for otitis media with effusion in a young child. The estimates of benefits and harms are shown as differences from the base case -- a target patient (a child age 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits who is otherwise healthy except for otitis media with effusion) whose otitis media with effusion is managed by observation. These differences are shown rather than actual study results, because studies differed in the rate at which otitis media with effusion cleared in the control arms. Where high-quality evidence on the probability or magnitude of an effect was available, the results are shown as a median and 95 percent confidence interval of the distribution that resulted from meta-analysis. More information about the estimates is contained in the sections of the Guideline that deal with the specific intervention; greater detail is provided in the Guideline Technical Report.

Table 1. Outcomes of treating otitis media with effusion [1]

Intervention Observation | Benefits ^[2]^ Base case. | Harms ^[2]^ Base case
Antibiotics | Improved clearance of effusion at 1 month or less, 14.0% (95% CI [3.6%,24.2%]). Possible reduction in future infections. | Nausea, vomiting, diarrhea (2%-32% depending on dose and antibiotic). Cutaneous reactions (<5%). Numerous rare organ system effects, including very rare fatalities. Cost. Possible development of resistant strains of bacteria.
Antibiotics plus steroids | Possible improved clearance at 1 month, 25.1% (95% CI [-1.3%,49.9%]).^[3]^ Possible reduction in future infections. | See antibiotics and steroids separately.
Steroids alone | Possible improved clearance at 1 month, 4.5% (95% CI [-11.7%, 20.6%]). ^[3]^ | Possible exacerbation of varicella. Long-term complications not established for low doses. Cost.
Antihistamine/ decongestant | Same as base case. | Drowsiness and/or excitability.^[4]^ Cost.
Intervention Myringotomy with tubes | Immediate clearance of effusion in all children. Improved hearing. | Invasive procedure. Anesthesia risk. Cost. Tympanosclerosis. Otorrhea. Possible restrictions on swimming.
Adenoidectomy | Benefits for young children have not been established. | Invasive procedure. ^[4]^ Anesthesia risk. Cost.
Tonsillectomy | Same as base case. | Invasive procedure. ^[4]^ Anesthesia risk. Cost.

[1] The target patient is an otherwise healthy child age 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits.

[2] Outcomes are reported as differences from observation, which is treated as the base case. When possible, meta-analysis was performed to provide a mean and associated confidence interval (CI).

[3] Difference from base case not statistically significant.

[4] Risks were not examined in detail because no benefits were identified.

## Long-Term Outcomes

Studies that link otitis media with effusion with hearing-related development did not use consistent measures of otitis media with effusion, hearing loss, and outcomes. However, the published data support the following trends: (1) a weak association between otitis media with effusion early in life and abnormal speech and language development of children younger than age 4 years; and (2) a weak association between early otitis media with effusion and delay in expressive language development and behavior (attention) in children over age 4 years. The effects of otitis media with effusion on other hearing-related domains are less clear.

The association between congenital or early-onset hearing impairment, particularly sensorineural hearing loss, and impaired speech and language development is well established (Ventry, 1980; Nober, 1967; Matkin, 1968): the earlier the onset and the more severe the hearing impairment, the greater the impairment in development of speech and language. Permanent sensorineural or conductive hearing loss leads to pronounced abnormalities in speech and language acquisition. In contrast, otitis media with effusion can produce mild to moderate conductive hearing impairment, which can fluctuate, remain stable, or alternate with periods of normal hearing. It is not known how many days of effusion and reduced hearing are required before development is adversely affected. Nevertheless, because permanent hearing loss can markedly affect communication, clinicians have hypothesized that the hearing impairment associated with persistent or recurrent episodes of otitis media with effusion at an early age may produce significant speech, language, cognitive, and educational delays and have advocated early, aggressive treatment of otitis media with effusion in young children. Thus, the Panel addressed this issue with particular interest, and rigorously reviewed and analyzed the available literature on hearing-related developmental outcomes of treated and untreated otitis media with effusion.

A search of the literature identified 101 published articles: 71 contained original data and 30 were review, anecdotal, or theoretical articles. None reported randomized, controlled clinical studies. The 71 articles with original data were examined in further detail: all but 35 were excluded from further consideration because: (1) they did not present sufficient developmental data; (2) otitis media with effusion was not documented before age 4; (3) researchers relied entirely on parental report for otitis media with effusion history; (4) they were retrospective studies that focused on children with speech disorders, language disorders, and/or learning disabilities; or (5) children had a biologic condition (such as cleft palate) that increased their risk of otitis media with effusion.

The 35 remaining studies were then classified with attention to the rigor of the experimental design, sample characteristics as they relate to the target population of this Guideline, and statistical analysis. Fourteen of the studies were considered adequate, and 11 were characterized by some limitation in methods such as retrospective design, use of medical record review to document otitis media with effusion history, or inclusion of a population at high risk. The remaining 10 had significant flaws that could compromise the validity of the results and their interpretation. Taken as a group, the principal characteristic of the 21 "suboptimal" studies was the presence of inconclusive and often contradictory results. Meta-analysis of the 14 adequate studies was not possible because of the marked diversity of measurement tools used for outcome assessment, as well as a lack of uniformity in the ways in which the data were presented. The Panel used expert opinion to judge the evidence (summarized in Table 2) addressing the following four main issues.

Table 2. Evidence on long-term outcomes of otitis media with effusion in younger children

Developmental domain | | Reference | No. of subjects | No. of controls | Design ^[1]^ | Test ^[2]^ | Age at study assessment (years) | Effects of otitis media with effusion ^[3]^
Speech | Receptive | Gravel and Wallace, 1992 | 10 | 13 | P,Co | PSI | 4 | S
Speech | Expressive | Roberts, Burchinal, Koch, et al., 1988 | 55 | 0 | P,Co | G-F-W | 2.5-8 | NS
Speech | Expressive | Teele, Klein, Chase, et al., 1990 | 194 | 0 | P,Co | G-F-W | 7 | S
Language | Receptive | Friel-Patti, Finitzo-Hieber, Conti, et al., 1982 | 35 | 0 | P,Co | REEL, SICD-R | 1-2 | S
Language | Receptive | Friel-Patti and Finitzo, 1990 | 483 | 0 | P,Co | SICD-R | 1-2 | NS 18,24m; S 12m
Language | Receptive | Gravel and Wallace, 1992 | 10 | 13 | P,Co | SICD-R | 4 | NS
Language | Receptive | Lous, Fiellau-Nikolajsen, and Jeppesen, 1988 | 26 | 26 | A,Ca | PPVT | 8 | NS
Language | Receptive | Rach, Zielhuis, and van den Broek, 1988 | 52 | 13 | P,Co | Reynell | 2-4 | NS
Language | Receptive | Rach, Zielhuis, van Baarle, et al., 1991 | 84 | 18 | P,Ca | Reynell | 4 | NS
Language | Receptive | Roberts, Burchinal, Davis, et al., 1991 | 63 | 0 | P,Co | M-Y, BLST, PPVT, CELF | 4-6 | NS
Language | Receptive | Teele, Klein, Rosner, et al., 1984 | 205 | 0 | P,Co | PPVT ACQ VAQ | 3 | S S NS
Language | Receptive | Teele, Klein, Chase, et al., 1990 | 194 | 0 | P,Co | PPVT, WUG | 7 | NS
Language | Receptive | Wright, Sell, McConnell, et al., 1988 | 156 | 0 | P,Co | PPVT, PLS, REEL, Boone | 2-4 | NS
Language | Expressive | Friel-Patti, Finitzo-Hieber, Conti, et al., 1982 | 35 | 0 | P,Co | REEL SICD-E | 1-2 | S
Language | Expressive | Feagans, Sanyal, Henderson, et al., 1987 | 44 | 0 | P,Co | Paraphrase MLU | 5,7 | S NS
Language | Expressive | Friel-Patti and Finitzo, 1990 | 483 | 0 | P,Co | SICD-E | 1-2 | NS 12,24m; S 18m
Language | Expressive | Rach, Zielhuis, and van den Broek, 1988 | 52 | 13 | P,Co | Reynell | 2-4 | S
Language | Expressive | Rach, Zielhuis, van Baarle, et al., 1991 | 84 | 18 | P,Ca | Reynell | 2-4 | S
Language | Expressive | Roberts, Burchinal, Davis, et al., 1991 | 63 | 0 | P,Co | CELF-E, MLU | 4-6 | NS
Language | Expressive | Teele, Klein, Chase, et al., 1990 | 194 | 0 | P,Co | Language Sample WUG, Boston | 7 | NS
Language | Expressive | Wright, Sell, McConnell, et al., 1988 | 156 | 0 | P,Co | PLS, REEL, Boone | 2-4 | NS
Other | Intelligence | Roberts, Sanyal, Burchinal, et al., 1986 | 61 | 0 | P,Co | WPPSI | 5,7 | S
Other | Intelligence | Roberts, Burchinal, Collier, et al., 1989 | 44 | 0 | P,Co | WISC-R | 8 | NS
Other | Behavior | Roberts, Burchinal, Collier, et al., 1989 | 44 | 0 | P,Co | CBI | 8 | S
Other | Behavior | Feagans, Sanyal, Henderson, et al., 1987 | 44 | 0 | P,Co | SCAN | 5,7 | S

[1] Abbreviations used for design: A = ambispective study (data collected by history as well as after enrollment in study). Ca = case control (data from children with the problem paired for comparison with data from children without variable). Co = cohort (group of children studied at different points in time). P = prospective study (data collected after enrollment in study).

[2] Abbreviations used for tests: ACQ = Auditory Comprehension Quotient (Zimmerman Preschool Language Scale). BLST = Bankson Language Screening Test. Boone = Boone Infant Speech and Language Development. Boston = Boston Naming Test. CBI = Classroom Behavior Inventory. CELF = Clinical Evaluation of Language Functions. G-F-W = Goldman-Fristoe-Woodcock Test of Articulation. MLU = Mean Length of Utterance. M-Y = Miller-Yoder Language Comprehension Test. PLS=Zimmerman Preschool Language Scale. PPVT=Peabody Picture Vocabulary Text. PSI=Pediatric Sentence Intelligibility Test. REEL=Receptive-Expressive Emergent Language Scale. Reynell=Reynell Developmental Language Scales. SCAN=Behavioral observation of task oriented, affective, and social actions. SICD=Sequenced Inventory of Communication Development. VAQ=Verbal Ability Quotient (Zimmerman Preschool Language Scale). WISC-R=Weschler Intelligence Scales for Children (Revised Versions). WPPSI=Weschler Preschool on a Primary Scale of Intelligence. WUG="WUG" Test.

[3] Abbreviations used for effect: NS=not statistically significant. S=significant (p <= 0.05).

### Does Untreated Otitis Media with Effusion Affect Speech, Language, and Development?

Zielhuis, Straatman, Rach, et al. (1990) reported that approximately 60 percent of the cases of otitis media with effusion resolved spontaneously without intervention within 3 months of onset, and 85 percent within 6 months. It is not clear, however, whether children whose effusions resolved by 3 months were still free of effusion at 6 months. The major long-term outcomes used to justify early and aggressive treatment of otitis media with effusion are developmental delays or deficits that might result from the mild to moderate hearing losses that often accompany middle ear effusions. The literature on this subject, however, does not present a uniform picture: the findings of different studies are contradictory.

The Panel found several studies that reported lower scores for children with histories of early, recurrent otitis media with effusion versus children without such histories on tests of vocabulary (Teele, Klein, Rosner, et al., 1984), auditory comprehension (Rach, Zielhuis, van Baarle, et al., 1991; Gravel and Wallace, 1992; Lous, Fiellau-Nikolajsen, and Jeppesen, 1988), semantics and syntax (Rach, Zielhuis, and van den Broek, 1988), auditory figure-ground discrimination (Gravel and Wallace, 1992), narrative skill (Feagans, Sanyal, Henderson, et al., 1987), and other discrete receptive and expressive language skills (Friel-Patti, Finitzo-Hieber, Conti, et al., 1982; Friel-Patti and Finitzo, 1990; Teele, Klein, Rosner, et al., 1984). Specific articulation and phonological errors have been described as well (Roberts, Burchinal, Koch, et al., 1988).

Other studies, however, have failed to find significant differences in some of these measures, even when using the same test instruments (Roberts, Sanyal, Burchinal, et al., 1986; Roberts, Burchinal, Davis, et al., 1991; Wright, Sell, McConnell, et al., 1988; Lous, Fiellau-Nikolajsen, and Jeppesen, 1988).

Some cohort studies reported greater variance within groups than between groups on standardized measures of speech or language (Lous, Fiellau-Nikolajsen, and Jeppesen, 1988), suggesting a complex relationship between developmental delays and otitis media with effusion. The Panel found that, despite documentation of performance deficits in some children who were prone to otitis media with effusion, the available literature fails to provide definitive support for the proposed causal relationship in three principal areas:

- There have been no randomized clinical studies in which otitis media with effusion has been left completely untreated in children with the intention of studying its long-term effects on speech, language, and hearing -- a problem influenced as much by ethical considerations as by the scientific method.
- Few studies have measured hearing levels in children, relying instead on frequency or duration of effusion as a predictive variable for developmental outcome.
- There is no consensus on which of the many aspects of speech, language, or learning are affected by early otitis media with effusion; thus, a broad array of test instruments have been used, leading to inconclusive or conflicting results among studies.

Experts theorize that persistent or fluctuating hearing loss produced by middle ear effusion degrades the incoming acoustic speech signal so that incomplete and inaccurate information is available for learning speech and language skills (Roberts, Sanyal, Burchinal, et al., 1986; Teele, Klein, Rosner, et al., 1984; Roberts, Burchinal, Koch, et al., 1988; Friel-Patti and Finitzo, 1990). Among the studies reviewed, however, there was little uniformity in reporting subjects' hearing levels.

Instead of directly documenting hearing, some researchers have used the number of episodes of otitis media with effusion or total number of days with otitis media with effusion within a certain period of time as the independent variable, on the assumption that the presence of otitis media with effusion is an adequate surrogate for the presence of hearing loss (type not specified) (Feagans, Sanyal, Henderson, et al., 1987; Gravel and Wallace, 1992; Rach, Zielhuis, and van den Broek, 1988; Rach, Zielhuis, van Baarle, et al., 1991; Roberts, Burchinal, Koch, et al., 1988; Roberts, Burchinal, Collier, et al., 1989; Roberts, Burchinal, Davis, et al., 1991; Teele, Klein, Rosner, et al., 1984; Teele, Klein, Chase, et al., 1990). Studies using this approach have yielded inconsistent results in both the direction and magnitude of effects.

Other researchers have used click-evoked auditory brainstem responses as an indicator of hearing level (Friel-Patti, Finitzo-Hieber, Conti, et al., 1982; Friel-Patti and Finitzo, 1990). Although threshold estimates for click-evoked auditory brainstem responses are not frequency specific, they more accurately reflect sensitivity in the high-frequency region (1,000 to 4,000 Hz) than in the lower frequencies. Because middle ear effusion typically produces a hearing loss most prominent for the low frequencies (below 1,000 Hz), auditory brainstem response recording has the potential to underestimate the degree of hearing loss from otitis media with effusion.

Although some reports specify details of hearing loss associated with otitis media with effusion, the available literature taken as a whole does not permit reliable estimates of the course of hearing loss during episodes of effusion. The literature also fails to provide information needed to estimate to what degree parameters of hearing loss (frequency, severity, and duration of loss; frequency and duration of periods of normal hearing; age of onset) influence speech, language, and other developmental outcomes. In general, hearing status appears to be a better predictor of developmental outcomes than does otitis media with effusion: that is, the literature points to a direct connection between hearing and language, and an indirect connection between otitis media with effusion and language, mediated by the relationship between otitis media with effusion and hearing (Friel-Patti and Finitzo, 1990). Empirical research to test this hypothesis is unlikely to be conducted, however, because of the difficulty of quantifying effects due to duration and severity of otitis media with effusion on the one hand and effects due to parameters of hearing loss on the other.

Many clinicians have tried to measure the effects on speech and language of hearing loss related to otitis media with effusion, but few agree as to which tests should be used to measure those functions: one review article identified 15 different language tests used in only 20 studies. Furthermore, the results varied among studies, even when the same test was used (Roberts, Burchinal, Davis, et al., 1991). For example, significant differences in performance on the Peabody Picture Vocabulary Test were found by some investigators (Holm and Kunze, 1969; Teele, Klein, Rosner, et al., 1984) but not by others (Brookhouser and Goldgar, 1987; Lous, Fiellau-Nikolajsen, and Jeppesen, 1988; Wright, Sell, McConnell, et al., 1988; Teele, Klein, Chase, et al., 1990). Similarly, children tested with the Reynell Developmental Language Scales have shown significant differences in some studies (Silva, Kirkland, Simpson, et al., 1982; Silva, Chalmers, and Stewart, 1986) but not in others (Rach, Zielhuis, and van den Broek, 1988; Brookhouser and Goldgar, 1987).

Moreover, although statistically significant performance differences can appear between cohort groups, the performances of both groups can fall within the normal ranges established for that test and age range. In such cases, the effect would be described most appropriately as language differences rather than delays. How such differences can affect development in cognitive, behavioral, and speech and language domains is unknown, just as the functional significance of isolated, specific test deficits is unclear. In addition, when test scores are scaled to age norms it is difficult to dissociate deficits from delays, and this problem has not been addressed in children with otitis media with effusion.

A related issue is whether developmental effects are long-lasting. Evidence that hearing changes associated with otitis media with effusion cause dysfunctions that persist into later childhood despite resolution of the otitis media with effusion and a return to normal hearing would provide a compelling argument for early, decisive intervention for otitis media with effusion. Available evidence, however, does not show a consistent effect of otitis media with effusion on language and/or learning once the disease process and its associated hearing loss have resolved (Wright, Sell, McConnell, et al., 1988; Teele, Klein, Chase, et al., 1990; Teele, Klein, Rosner, et al., 1984; Roberts, Burchinal, Davis, et al., 1991; Roberts, Burchinal, Collier, et al., 1989; Roberts, Burchinal, Koch, et al., 1988; Lous, Fiellau-Nikolajsen, and Jeppesen, 1988; Rach, Zielhuis, and van den Broek, 1988; Gravel and Wallace, 1992; Feagans, Sanyal, Henderson, et al., 1987).

### Does Treatment of Otitis Media with Effusion Affect Subsequent Speech and Language Development?

A fundamental assumption underlying the treatment of disease is that the treatment will reduce or eliminate the effects of the disorder. Otitis media with effusion can be treated medically, surgically, and/or by control of environmental risk factors; clearing of the effusion results in restoration of normal hearing levels in almost all cases, although the condition can recur and require further treatment. Both short- and long-term outcomes of treatment are of interest.

The immediate restoration of normal hearing with removal of the middle ear effusion is well documented, and there appear to be few long-term residual effects on hearing sensitivity, barring complications such as cholesteatoma, tympanosclerosis, or chronic tympanic membrane perforation (Wright, Sell, McConnell, et al., 1988).

Long-term developmental outcomes of treated and untreated otitis media with effusion have, however, not been compared in randomized controlled clinical studies. One study (Rach, Zielhuis, van Baarle, et al., 1991) compared verbal comprehension and expression in a sample (n = 52) of preschool children with short-term (3 to 6 months) and long-term (6 months or longer) otitis media with effusion; half were treated with bilateral myringotomy and tubes, and the other half received no treatment. At the end of a 6-month followup, language development was assessed and compared with assessments of age-matched children without otitis media with effusion. The results indicated a trend toward improved language development either by treatment with tubes or by time alone, although improvement after treatment seemed to be slightly faster. An additional finding of the study was that spontaneous improvement in language development occurred more readily in children who had had otitis media with effusion for less than 6 months. Despite a trend toward greater improvement in the treatment groups, there was no statistically significant difference between the treated and untreated groups on the Reynell Developmental Language Scales test.

Other studies reviewed by the Panel followed otitis-prone children for periods of up to 7 years after the history of otitis media with effusion was established (Roberts, Sanyal, Burchinal, et al., 1986; Feagans, Sanyal, Henderson, et al., 1987; Lous, Fiellau-Nikolajsen, and Jeppesen, 1988; Roberts, Burchinal, Koch, et al., 1988; Roberts, Burchinal, Davis, et al., 1991; Teele, Klein, Chase, et al., 1990). The results of these studies are mixed. Most studies indicated that conventional treatment approaches (such as antibiotic therapy or myringotomy with tubes) were used when effusion was present, but the results were not stratified for treatment or age at intervention. Instead, the outcome measures were temporal variables, such as documented days with effusion. By inference, therefore, most children in the reported samples had been treated; some showed long-term effects on receptive or expressive language, but others did not.

### Given What Is Known About Speech and Language Development, Is There a Best Time to Treat Otitis Media with Effusion?

The foundations for auditory-verbal skills are laid and refined largely within the first several years of life, the same years in which the incidence of otitis media with effusion is highest (Feagans, Sanyal, Henderson, et al., 1987). The results of longitudinal studies are in agreement that the more time spent with otitis media with effusion and its related hearing loss during the first 3 years, the greater the probability that speech and language deficits will result (Teele, Klein, Rosner, et al., 1984; Teele, Klein, Chase, et al., 1990; Friel-Patti and Finitzo, 1990; Rach, Zielhuis, and van den Broek, 1988). Some have also found that children who have multiple episodes of otitis media with effusion early in life are likely to continue to have that disease (Teele, Klein, Chase, et al., 1990; Teele, Klein, Rosner, et al., 1984; Rach, Zielhuis, and van den Broek, 1988).

The association between brief periods of mild, fluctuating hearing loss and subsequent development is less clear. There seems to be little long-term effect of otitis media with effusion that appears for the first time after age 3 (Teele, Klein, Rosner, et al., 1984), lending support to the concept of a "critical period" for acquisition of communication skills; during this period, sensory deprivation or attenuation of auditory signals can exert more significant effects than they would later in life. This association appears across all study designs, sample characteristics, and tests used.

### Are There Variations in Middle Ear Condition That Would Influence a Management Protocol?

Variations in middle ear status that can influence choice of treatment fall into three categories: those that are unusually severe, carrying a high risk of additional complications; those that are exceptionally mild or that involve only one ear; and those that occur in children with pre-existing sensory deficits. Complications of disease (such as cholesteatoma, adhesions, and tympanic membrane perforation) are not considered here.

Although mild conductive hearing loss generally accompanies otitis media with effusion, middle ear effusions can be present with minimal effects on hearing. Despite studies that have reported a close association between the persistence of otitis media with effusion and speech and language development (Teele, Klein, Rosner, et al., 1984; Teele, Klein, Chase, et al., 1990; Friel-Patti and Finitzo, 1990; Rach, Zielhuis, and van den Broek, 1988), there is no evidence that when hearing remains "normal" there is any effect of otitis media with effusion per se on speech and language. There is no agreement, however, as to the minimal hearing sensitivity necessary for infants and young children to complete the complex process of developing speech and language successfully. In the absence of such a standard, when hearing is within normal limits (defined as less than 20 decibels hearing threshold level) in at least one ear, the Panel recommends against bilateral myringotomy with tubes.

A related problem is seen in the case of persistent unilateral otitis media with effusion. Some have suggested that hearing asymmetry plays a significant role in the development of speech/language delays or disorders (Roberts, Burchinal, Koch, et al., 1988). In about two-thirds of cases (Casselbrant, Brostoff, Cantekin, et al., 1985) otitis media with effusion occurs bilaterally, although the extent of middle ear abnormality -- and with it, hearing -- can vary between ears. Most studies considered by the Panel either did not track unilateral versus bilateral otitis media with effusion or did not stratify the study samples on that basis when analyzing results. Unilateral hearing loss is known to interfere with normal localization of sound in space and in auditory figure-ground discrimination (Oyler, Oyler, and Matkin, 1987). However, the effects of the typical mild to moderate hearing loss associated with otitis media with effusion on these functions have not been well studied. Within the past 5 years, some evidence has appeared for effects of unilateral and bilateral hearing impairment on certain tests of central auditory function, such as auditory brainstem response recording and the binaural masking level difference test (Hall and Grose, 1993; Pillsbury, Grose, and Hall, 1991). Although the results of these studies are provocative, the effects measured were small, and it is not clear what significance the findings have with regard to the acquisition and refinement of speech and language skills in younger children.

Two conditions merit special consideration in management decisions for otitis media with effusion, although they are beyond the scope of this guideline: (1) when the otitis media with effusion occurs in the only- or better-hearing ear, as with congenital atresia; and (2) when the otitis media with effusion occurs in a child with a known sensorineural hearing loss or severe visual or mental deficit. In each of these circumstances, the impact of even a mild conductive hearing loss can be substantially greater to the child attempting to learn speech and language skills without the full complement of sensory abilities. When overlaid on a pre-existing sensorineural loss, a conductive impairment reduces the child's ability to use hearing aids and assistive listening devices to acquire auditory-verbal communication skills.

In summary, the Panel found that rigorous, methodologically sound research does not adequately support or refute the theory that untreated otitis media with effusion results in speech/language delays or deficits. Conflicting findings among studies can be accounted for in several ways: limitations in the research designs, lack of uniformity of test instrument selection, lack of definition of hearing status, and interactions between otitis media with effusion and other risk factors (Roberts, Burchinal, Davis, et al., 1991).