# Guideline: Summary of Recommendations

The Panel developed clinical options and made recommendations for diagnosis, evaluation, and management of otitis media with effusion in otherwise healthy children ages 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits. The recommendations are based on the results of the literature review and the expert opinion of the Panel. They are summarized here, followed by a corresponding algorithm. Details and rationale for the recommendations are given in subsequent chapters.

## Diagnosis of Otitis Media with Effusion and Evaluation of Hearing

- Pneumatic Otoscopy -- Recommendation: The diagnostic evaluation of suspected otitis media with effusion should include pneumatic otoscopy. Otoscopy alone (without the use of the pneumatic otoscope to test tympanic membrane mobility) is not recommended. [Strong recommendation based on limited scientific evidence and strong Panel consensus.]
- Tympanometry -- Option: Tympanometry may be used as a confirmatory test for otitis media with effusion. [Option based on limited scientific evidence and expert opinion.]
- Acoustic Reflectometry -- No Recommendation: No recommendation is made regarding the use of acoustic reflectometry as a screening or diagnostic test for otitis media with effusion.
- Tuning Fork Tests -- No Recommendation: No recommendation is made regarding the use of tuning fork tests in screening for or diagnosis of otitis media with effusion, except to note that they are inappropriate in the youngest children.
- Hearing Evaluation -- Option: Hearing evaluation may be performed before otitis media with effusion has been present for a total of 3 months. [Option based on insufficient evidence.]
- Hearing Evaluation -- Recommendation: Hearing evaluation is recommended for a child who has had bilateral otitis media with effusion for a total of 3 months. [Recommendation based on limited scientific evidence and expert opinion.]

## Management

The Panel decided upon options and made recommendations for management of the otherwise healthy child age 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits (except as noted in the recommendations) who enters the management algorithm with otitis media with effusion. Management is discussed for (1) initial presentation, (2) after a total of 3 months of otitis media with effusion, and (3) when otitis media with effusion has continued for a total of 4 to 6 months. These guidelines may be modified to fit the needs of the individual patient.

### Visit Interval

The Panel found no evidence regarding optimal visit intervals. A visit interval of 6 weeks was assumed in preparing these recommendations.

### Initial Management

- Observation OR Antibiotic Therapy -- Option: Observation OR antibiotic therapy may be chosen for management of otitis media with effusion in an otherwise healthy child. [Option based on limited scientific evidence and Panel consensus.]
- Environmental Risk Factor Control -- Option: Parents should be encouraged to control environmental risk factors. [Option based on limited scientific evidence and strong Panel consensus.]
- Myringotomy -- Recommendation: Myringotomy with or without insertion of tympanostomy tubes should NOT be performed for initial management of otitis media with effusion in an otherwise healthy child. [Strong recommendation based on evidence that otitis media with effusion resolves spontaneously in most cases and lack of conclusive evidence that a short period of otitis media with effusion has deleterious effects on otherwise healthy children.]

### After 3 Months

If the child has hearing in the normal range, as indicated by a hearing threshold level better than 20 decibels in the better-hearing ear, recommendations are as follows:

- Observation OR Antibiotic Therapy -- Option: Observation OR antibiotic therapy may be chosen. [Option based on limited scientific evidence and Panel consensus.]
- Environmental Risk Factor Control -- Option: Parents should be encouraged to control environmental risk factors. [Option based on limited scientific evidence and strong Panel consensus.]

If the child has bilateral hearing deficits of 20 decibels hearing threshold level or worse, recommendations are as follows:

- Antibiotic Therapy OR Myringotomy with Tubes -- Option: Antibiotic therapy OR bilateral myringotomy with insertion of tympanostomy tubes may be chosen to manage bilateral otitis media with effusion that has lasted a total of 3 months in an otherwise healthy child age 1 through 3 years who has a bilateral hearing deficit (defined as 20 decibels hearing threshold level or worse in the better-hearing ear). [Based on limited scientific evidence and Panel consensus.]
- Environmental Risk Factor Control -- Option: Parents should be encouraged to control environmental risk factors. [Option based on limited scientific evidence and strong Panel consensus.]

### After 4 to 6 Months

- Myringotomy with Tubes -- Recommendation: Bilateral myringotomy with insertion of tympanostomy tubes is recommended to manage bilateral otitis media with effusion that has lasted a total of 4 to 6 months in an otherwise healthy child age 1 through 3 years who has bilateral hearing deficit (defined as 20 decibels hearing threshold level or worse in the better-hearing ear). [Moderate recommendation based on limited scientific evidence and strong Panel consensus.]
- Environmental Risk Factor Control -- Option: Parents should be encouraged to control environmental risk factors. [Option based on limited scientific evidence and strong Panel consensus.]

### Not Recommended at Any Time

- Steroid Therapy -- Recommendation: Steroid medications are not recommended for treatment of otitis media with effusion in a child of any age. [Based on limited scientific evidence and Panel majority opinion.] The Panel makes no statement regarding the use of steroid medications for conditions other than otitis media with effusion.
- Antihistamine/Decongestant Therapy -- Recommendation: Antihistamine and/or decongestant agents are not recommended for treatment of otitis media with effusion. [Strong recommendation based on evidence that can be generalized to a child of any age.] The Panel makes no statement regarding the use of antihistamine and/or decongestant medications for conditions other than otitis media with effusion.
- Adenoidectomy -- Recommendation: Adenoidectomy is not recommended for treatment of otitis media with effusion in a child age 1 through 3 years in the absence of specific adenoid pathology. [Based on limited scientific evidence and Panel majority opinion.]
- Tonsillectomy -- Recommendation: Tonsillectomy should not be performed, either alone or with adenoidectomy, for the treatment of otitis media with effusion in a child of any age. [Strong recommendation based on limited scientific evidence and strong Panel consensus.]

### No Recommendation

- Allergy Management -- No Recommendation: No recommendation is made regarding allergy management as treatment for otitis media with effusion in the otherwise healthy child age 1 through 3 years. [Based on insufficient evidence clarifying the relationship between allergy and otitis media with effusion.]
- Other Therapies -- No Recommendation: No recommendation is made regarding other therapies (chiropractic, holistic, naturopathic, traditional or indigenous, homeopathic) for the treatment of otitis media with effusion in the otherwise healthy child age 1 through 3 years. [Based on lack of scientific evidence.]

## Algorithm

The notes below are an integral part of the algorithm that follows.

[Algorithm, part 1] [Algorithm, part 2] [Algorithm, part 3]

Algorithm 1 Part 1. Algorithm for managing otitis media with effusion in an otherwise healthy child age 1 through 3 years

Algorithm 1 Part 2. Algorithm for managing otitis media with effusion in an otherwise healthy child age 1 through 3 years

Algorithm 1 Part 3. Algorithm for managing otitis media with effusion in an otherwise healthy child age 1 through 3 years

### Notes to Algorithm

1. Otitis media with effusion (OME) is defined as fluid in the middle ear without signs or symptoms of infection; OME is not to be confused with acute otitis media (inflammation of the middle ear with signs of infection). The Guideline and this algorithm apply ONLY to the child age 1 through 3 years with no craniofacial or neurologic abnormalities of sensory deficits who is otherwise healthy except for otitis media with effusion. For the purpose of this algorithm, the Panel assumed followup intervals of 6 weeks.
2. The algorithm applies only to a child age 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits (except as noted) who is healthy except for otitis media with effusion. The Guideline recommendations and algorithm DO NOT apply if the child has any craniofacial or neurologic abnormality (for example, cleft palate or mental retardation) or sensory deficit (for example, decreased visual acuity or pre-existing hearing deficit).
3. Pneumatic otoscopy is defined and described in Chapter 4, "Diagnosis and Hearing Evaluation" (page 29), and in the Glossary. The Panel found some evidence, reported in Chapter 4, that pneumatic otoscopy is more accurate than otoscopy performed without the pneumatic test of eardrum mobility.
4. Tympanometry and hearing evaluation are discussed in Chapter 4 and defined in the Glossary. Tympanometry (page 32) may be used as confirmation of pneumatic otoscopy (page 30) in the diagnosis of otitis media with effusion (OME). Hearing evaluation (page 35) is recommended for the otherwise healthy child who has had bilateral OME for 3 months; before 3 months, hearing evaluation is a clinical option.
5. In most cases, otitis media with effusion (OME) resolves spontaneously within 3 months (Zielhuis, Straatman, Rach, et al., 1990).
6. The antibiotic drugs studied for treatment of otitis media with effusion (OME) were amoxicillin, amoxicillin-clavulanate potassium, cefaclor, erythromycin, erythromycin-sulfisoxazole, sulfisoxazole, and trimethoprim-sulfamethoxazole. The Panel's findings regarding antibiotic drugs for OME are given in Chapter 6, "Pharmaceutical Therapies" (page 41).
7. Exposure to cigarette smoke (passive smoking) has been shown to increase the risk of otitis media with effusion (OME), as documented in Chapter 5 "Control of Environmental Risk Factors" (page 37). For bottle-feeding versus breast-feeding and for child-care facility placement, associations were found with OME, but evidence available to the Panel did not show decreased incidence of OME with breast-feeding or with removal from child-care facilities.
8. The recommendation against tonsillectomy is based on the lack of added benefit from tonsillectomy when combined with adenoidectomy to treat otitis media with effusion in older children. Tonsillectomy and adenoidectomy may be appropriate for reasons other than otitis media with effusion. See Chapter 7, "Surgical Therapies" (page 55).
9. The Panel found evidence that decongestants and antihistamines are ineffective treatments for otitis media with effusion, as documented in Chapter 6, "Pharmaceutical Therapies" (pages 53-54).
10. Meta-analysis failed to show a significant benefit for steroid medications without antibiotic medications in treating otitis media with effusion in children, as reported in Chapter 6, "Pharmaceutical Therapies" (pages 50-53).