# Research Issues

Members of the Panel were disappointed to find the medical literature voluminous but unenlightening on many important issues related to otitis media with effusion. General areas in which research studies are needed include natural history, diagnosis, prevention, interventions for, and long term outcomes of otitis media with effusion. The Panel hopes that well-designed randomized controlled studies will be conducted to answer the many important questions raised in its evidence-based review of the literature for development of this Guideline.

## Natural History

It is characteristic of health care providers in the United States to intervene for otitis media with effusion, but the Panel was impressed by data suggesting that otitis media with effusion usually follows a benign course without treatment. Thus, although such a study might be difficult to implement because it runs counter to prevailing attitudes, research to document the natural course of otitis media with effusion is essential to the identification of factors that separate children at risk for serious consequences of this condition -- and who therefore require treatment- from those who will do well if otitis media with effusion is not treated.

A key issue in research into the natural history of otitis media with effusion is the putative association of this condition with long-term adverse effects on speech and language development, learning, and behavior. There is general agreement that not treating a significant and/or long-lasting hearing impairment associated with otitis media with effusion could cause serious disability. However, little is known about the effects that fluctuating hearing loss can have on the long-term outcomes for otherwise normal children. Studies must be conducted to identify the combinations of patient characteristics and hearing loss that indicate risk of long-term problems. Factors that must be studied include:

- Child's age at onset of the hearing impairment.
- Duration of the hearing impairment.
- Severity of the hearing impairment.
- Child's social environment.
- Effect of fluctuation of hearing.

High-quality descriptive research studies are essential to definition of the proximal and long-term effects of hearing loss on speech, language, learning, and behavioral outcomes. Some of the linkages in the causal chain can be examined in children with hearing loss from causes other than otitis media with effusion.

## Diagnosis

No data have been reported on the use of otoscopy and pneumatic otoscopy in typical practice settings, although these two tests are the foundation upon which diagnostic and treatment decisions are made by many, if not most, clinicians. Similarly, tympanometry is used by many clinicians, alone or in combination with otoscopy, to evaluate for otitis media, and yet the methods for and results of performing tympanometry in typical practice settings, especially in primary care, have not been documented. The Panel recommends that:

- Diagnostic criteria be clarified for use of otoscopy, pneumatic otoscopy, and tympanometry in typical practice settings, particularly primary care.
- A diagnostic algorithm combining tympanometry and pneumatic otoscopy -- similar to that used in research -- be developed for use in clinical practice settings.
- The correlation of hearing evaluation results with otitis media with effusion be examined in large study populations representative of those cared for in a typical clinical practice.

## Control of Environmental Risk Factors

Available research suggests that environmental factors are associated with otitis media with effusion, but the data are descriptive and study results are open to criticism because of the research methods employed. Studies of impeccable design are needed on the associations between factors such as infant feeding practices, cigarette smoke, allergens, and child-care situations and the incidence, duration, complications, and other characteristics of otitis media and otitis media with effusion. Once associations have been identified, intervention studies should be conducted to determine the nature of the linkage(s) and whether controlling for the environmental factor(s) results in improved outcome for children with otitis media with effusion.

## Intervention

Clinical studies must be conducted to determine whether treatment of any kind improves the outcome of otitis media with effusion in children. The studies must be designed:

- To involve enough children for the results to be statistically commanding.
- To involve patient populations similar to those seen in typical practice.
- To control adequately for multiple confounding variables so that the results are clinically meaningful.

The best studies to meet these needs would be multicenter. In addition, they must be long-term, because the most important clinical outcomes of otitis media with effusion in children (speech, language, learning, behavior) may not be known until years after the intervention. For this reason, any recommendations, such as those made by the Panel in this Guideline, must be considered provisional until the results of such high-quality, long-term research confirm or refute their value.

### Antibiotic Therapy

Although the Panel found a large body of literature on antibiotic therapy for otitis media with effusion, major deficiencies in study designs precluded consideration of much of the data. A second problem with reports of antibiotic drug studies is the tendency for investigators and scientific journal editors to publish only reports of studies in which a positive effect of the therapy is demonstrated. Thus, the Panel viewed somewhat skeptically even the small number of reports of well-designed antibiotic therapy studies that met criteria for inclusion in the evidence for Guideline development.

The Panel believes that clinical studies are urgently needed to examine the issues related to antibiotic therapy for otitis media with effusion. Such studies should:

- Involve large study populations.
- Involve study populations representative of typical clinical practice.
- Be placebo controlled.
- Measure clinically important outcomes.
- Measure patient compliance with the drug regimen.
- Document antibiotic resistance.
- Document adverse events.
- Establish sequence and duration of therapy with various antibiotic agents.

### Steroid Therapy

The Panel found provocative but unconvincing recently reported data on the effectiveness of steroid medications alone and in combination with antibiotic agents to treat otitis media with effusion. Studies are needed in this area, and should:

- Involve large study populations.
- Involve study populations representative of typical clinical practice.
- Measure clinically important outcomes.
- Focus on a small number of antibiotic-steroid combinations.
- Identify the drug treatments that provide the best balance of high efficacy, low cost, and minimal number and severity of adverse effects.

### Surgery

The long-term effects of surgery on speech, language, learning, and behavior have not been identified. In addition, little is known about the short-term benefits of surgery other than relief from middle ear effusion. Future research should include the development of methods to measure the child's and parent's experiences of the operation. In particular, studies are needed to quantify the observations of parents, reported so often anecdotally by practitioners, that the child improves in sleep, behavior, communication, and other ways after surgery. Future research is also needed to determine whether the effects of adenoidectomy in reducing morbidity and number of recurrences in otitis media with effusion can be generalized to younger children in the 1 to 3 year age range.

### Allergy

The proposed linkage between allergy and otitis media with effusion is biologically plausible and, if validated, might open up important new avenues for intervention. High-quality descriptive studies should be followed by randomized controlled studies of therapy, focusing on clinically important outcomes as suggested for drugs and surgery.

### Other Therapies

The Panel found the process of the Open Meeting, during which many individuals provided interesting testimony on other therapies, both enlightening and disappointing. The Panel was impressed by the variety and apparent safety of many of the proposed therapies, but was disappointed that none had been submitted to scientific study. The Panel suggests that research begin with those other therapies commonly provided that appear the least likely to have adverse effects. Study designs should be similar to those proposed for evaluation of drugs and surgery.