# Cost Impact

The Panel commissioned an analysis of the cost of treating otitis media with effusion in young children. The contractor (Lewin-VHI, Inc.) was asked to determine current costs of treating otitis media with effusion and the potential impact on those costs of the Panel's recommendations for management. The full report will be available as an appendix to the Guideline Technical Report.

The cost analysis was complicated by several factors:

- Direct cost data were not available. The contractor used charges recorded in a health care claims data base compiled from more than 100 insurance companies by MEDSTAT Systems, Inc. Claims for all patients with specific ICD-9-CM diagnosis codes were extracted, thus removing claims for patients over age 17, those with nonrelevant medical care (i.e., intercurrent visit for another problem), and those with incomplete records, leaving a final working file of 129,081 outpatient claims and 579 inpatient claims covering 18,357 patients.
- Otitis media with effusion is a disease of children that can extend over many months, making it difficult to obtain complete information about a full episode of illness.
- Otitis media with effusion and recurrent acute otitis media overlap in claims data because of the use of nonspecific codes for otitis. Thus, although care was taken to use only selected codes (ICD-9-CM diagnostic codes 381.1 through 391.4) to retrieve data for Guideline cost analysis, researchers could not control for possible miscoding by health care providers or their staff. In addition, the codes used are for "chronic otitis," and these codes could mask a number of middle ear and upper airway conditions. Furthermore, the costs of treating otitis media with effusion are difficult to identify when charges are made at the same visit for other health care (e.g., concurrent medical care or well-child care).
- Costs of pharmacotherapy were not often included in the insurance claims data base because they are not usually covered by insurance. Thus, costs of pharmacotherapy were estimated by consulting standard published drug pricing information (the 1991 Drug Red Book) and adding the median Medicaid dispensing fee.
- Indirect cost estimates were limited to time and wages lost by parents, using 1991 Median Daily Earnings from the Bureau of Labor Statistics.
- Estimates include use of a therapy, initially considered an option by the Panel, that later in Guideline development was not recommended.

The results of the analysis show that 42 percent of children in the sample studied underwent myringotomy with tube placement and 6 percent underwent adenoidectomy; the remainder were treated nonsurgically.

Patients treated without surgery averaged 4.6 office visits, whereas those who underwent myringotomy with tube insertion averaged 5.5 office visits and those who underwent adenoidectomy averaged nearly 7 office visits for preoperative and postoperative treatment of an episode of otitis media with effusion.

Hearing testing was performed for 25.4 percent, 39.6 percent, and 44.6 percent of the children treated medically only, by myringotomy with tube insertion (before surgery), or by adenoidectomy (before surgery).

Extrapolating from data obtained for the cost analysis, it was estimated that 821,700 cases of otitis media with effusion occurred in 2-year-old children in 1991 and that $1.09 billion was actually spent for direct and indirect costs of care in these cases. The average cost per case across all treatment categories was $1,330. The average total costs per patient were $406, $2,174, and $3,433, respectively, for those treated medically, with myringotomy and insertion of tympanostomy tubes, and with adenoidectomy.

Predicting what might happen if the algorithm proposed in this Guideline entirely replaced current practice is hazardous because of the sensitivity of the result to many assumptions made during the process of cost analysis and to inherent limitations of claims-based data. For example, some of the parameters (e.g., an estimate that 30 percent of office visits coded as otitis media were for otitis media with effusion) were simply estimated by the Panel because data were unavailable. Despite the lack of adequate data, costs were calculated for care of otitis media with effusion in 2-year-old U.S. children in 1991 using strict adherence to the Guideline. The savings predicted were considerable (Table 7).

Table 7. Estimated 1991 costs of treating otitis media with effusion if Guideline recommendations had been implemented (United States, 2-year-old children)

Cost component | 1991 dollar amount ^[1]^ | Percentage of total cost ^[1]^
Total cost | $246.6 million | 100.0
Total cost incurred in first 3 months | $118.8 million | 48.2
Cost of surgical treatment | $80.3 million | 32.6
Indirect costs | $77.1 million | 31.3
Pharmaceutical costs | $16.8 million | 6.8

[1] Because most of the components overlap, the sums of the last four rows are greater than the total cost given in the first row.

Source: Lewin-VHI, Inc.

The Panel found no literature that examined the costs of treating otitis media with effusion in such a way that the results could be applied directly to Guideline recommendations. After completing the rigorous evidence-based review conducted to arrive at recommendations for clinical interventions for otitis media with effusion, the Panel was skeptical about depending upon a single cost analysis for estimating how implementing these recommendations would affect costs of care. Some Panelists thought the Guideline recommendations closely approximated current practice; thus, the prediction that application of the Guideline might result in significant cost savings raised concerns about the methods used for cost analysis. In particular, the estimate from the claims data that 42 percent of children with otitis media with effusion underwent myringotomy with insertion of tympanostomy tubes was met with skepticism by some of the Panel members, because it is much higher than the percentage they have observed in clinical practice. Other Panel members viewed the Guideline recommendations as more conservative than current practice with respect to surgery and were not surprised by the prediction that application of the recommendations might lead to fewer surgical interventions and lower costs. In the aggregate, the Panel views the contractor's cost estimates as representing the extreme of what might occur if the Guideline recommendations were implemented. Individual Panel members' estimates of the effect of Guideline implementation on costs of care for otitis media with effusion ranged from no effect to significant savings in direct and indirect costs of managing this condition.