# Overview

The term otitis media refers to a broad range of clinical conditions, from acute to chronic, both asymptomatic and symptomatic. Otitis media occurs in all age groups and has many different causes. The Panel followed methods recommended by the Agency for Health Care Policy and Research to focus the Otitis Media Clinical Practice Guideline on a specific clinical problem. In narrowing the scope of the guideline project, the Panel sought to identify a specific condition that is prevalent, has been the subject of variation or controversy in management, and can have long-term effects on function. Otitis media with effusion in young children met these criteria: it is prevalent, its management is highly controversial, and it is thought by some experts to be associated with later language, learning, and behavioral problems.

## Purpose and Scope of the Guideline

The purpose of the Clinical Practice Guideline on Otitis Media with Effusion in Young Children is to assist those who provide health care to young children in identifying and managing otitis media with effusion.

To meet constraints for Guideline development, the Panel focused the Guideline narrowly on management of otitis media with effusion in a "target child" age 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits, otherwise healthy except for otitis media with effusion. In most cases, the Panel's findings regarding the effects of bilateral otitis media with effusion on hearing-related development and the timing of diagnostic tests/hearing evaluation and interventions to manage otitis media with effusion are described for this "target child." When possible, Guideline recommendations are broadened to include older children. The Panel also considered costs and availability of health care resources to manage otitis media with effusion in young children.

## Organization of the Guideline

This first chapter of the Guideline provides background on otitis media with effusion, including prevalence of otitis media, and discusses the "target" patient for whom Guideline recommendations were formulated. Chapter 2 outlines the results of the Panel's evaluation of the literature on otitis media with effusion. The results are presented in the form of statements of options or recommendations and an algorithm for diagnosis, evaluation, and management. Chapter 3 presents the short-term and long-term outcomes of otitis media with effusion. Diagnostic issues regarding otitis media with effusion in children are addressed in Chapter 4.

Chapter 5 discusses control of environmental risk factors for otitis media with effusion. Chapter 6 reviews pharmaceutical interventions, and Chapter 7 reviews the Panel's findings regarding surgical interventions. Chapter 8 discusses results of the Panel's study of the association of allergy with otitis media with effusion, and Chapter 9 reviews findings regarding other treatments for this condition. Cost impacts of otitis media with effusion in children are presented in Chapter 10. In Chapter 11, research issues identified by the Panel are listed.

## Target Population, Settings, and Providers of Care

Following methods recommended by the Agency for Health Care Policy and Research for guideline development, the Otitis Media Guideline Panel defined a "target patient" to narrow the scope of the literature review. The Panel also identified practice settings and providers of care to the target patient.

The target patient is a child age 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits, otherwise healthy except for otitis media with effusion.

The Panel developed the Guideline for use in any setting in which children at risk of otitis media with effusion would be identified or treated, including physician offices, outpatient clinics, hospital emergency departments or urgent care centers, and schools or child-care facilities.

The Guideline is intended for use by providers of health care to young children, including primary care and specialist physicians, professional nurses and nurse practitioners, physician assistants, audiologists, speech and language pathologists, child development specialists, and consumers.

## Definition and Prevalence of Otitis Media with Effusion

The term otitis media (inflammation of the middle ear) encompasses a number of clinical conditions, each called by a variety of names. Statistics compiled by the National Center for Health Statistics (Schappert, 1992) and the results of longitudinal studies provide information about the incidence of and risk factors for otitis media.

Otitis media is the diagnosis made most frequently at visits by children younger than age 15 years to office-based physicians in the United States. Furthermore, the estimated 24.5 million visits for otitis media made in 1990 represented an increase of nearly 150 percent over the number of such visits made in 1975 (Schappert, 1992). In a large pediatric office practice in Boston, approximately one visit in three made for illness of any kind resulted in the diagnosis of middle ear disease; three-quarters of all followup visits for illness were made for disease of the middle ear (Teele, Klein, Rosner, et al., 1983).

A type of otitis media called otitis media with effusion is characterized by fluid in the middle ear without evidence of ear infection. Other terms used for otitis media with effusion in the literature include:

serous otitis media | mucoid otitis media | tympanic hydrops
secretory otitis media | secondary otitis media | glue ear
allergic otitis media | hydrotubotympanum | fluid ear
catarrhal otitis media | exudative catarrh | middle ear effusion
nonsuppurative otitis media | tubotympanitis | tubotympanic catarrh

The major symptoms associated with otitis media with effusion include discomfort and behavior changes.

The Panel did not find scientific evidence regarding the frequency with which the specific diagnosis of otitis media with effusion is made for children visiting ambulatory health care facilities in the United States. For the purposes of guideline development, the Panel estimated that in 25 to 35 percent of cases cited in the National Center for Health Statistics report (Schappert, 1992), the diagnosis "otitis media" represented otitis media with effusion.

The prevalence and natural history of otitis media with effusion have been reported in several research studies. However, much of the data include children in group child-care settings, which are a very select population. Also, the data include different, overlapping age groups. A 2-year study of 103 children age 2 to 6 years in group child care in the United States showed that 53 percent had at least one episode of otitis media with effusion during the first year of the study and 61 percent in the second year; 30 percent of the children had recurrent bouts of otitis media with effusion (Casselbrant, Brostoff, Cantekin, et al., 1985). A study of school children 5 to 12 years old found the incidence of otitis media with effusion to be much lower in children 6 years and older than in younger children (Casselbrant, Brostoff, Cantekin, et al., 1986), in keeping with the decreasing prevalence with increase in age reported by the National Center for Health Statistics (Schappert, 1992).

Otitis media with effusion cleared within 2 months in 80 percent of 103 children age 2 to 6 years in group child care in the United States (Casselbrant, Brostoff, Cantekin, et al., 1985). In a cohort study of 1,439 Dutch children, approximately 60 percent had recovered from the episode of otitis media with effusion without intervention after 3 months (Zielhuis, Straatman, Rach, et al., 1990). The latter clearance rate is cited throughout the Guideline because of the study's large sample size.

## Methods for Guideline Development

The Consortium (American Academy of Pediatrics, American Academy of Family Physicians, and American Academy of Otolaryngology -Head and Neck Surgery) received 37 names from 32 organizations and 2 individuals for nomination to the interim panel. After review of the nominations, the Consortium recommended a 15-member interim panel to the Agency for Health Care Policy and Research based on nominees' expertise, geographic location, race, and gender. Subsequently, a notice was published in the December 2, 1991, Federal Register and sent to the 32 organizations already solicited and 8 other organizations. From the resulting 18 additional panel nominations, the Consortium recommended adding 4 additional members to the panel. With Agency for Health Care Policy and Research approval, the Consortium appointed an Otitis Media Guideline Panel consisting of 17 Panel members and 2 Panel co-chairs. The Panel held four 2-day meetings over a 14-month period.

The Panel based their approach to guideline development on Agency for Health Care Policy and Research recommendations and the principles of Eddy (1992). The Panel was introduced to Eddy's principles of evidence-based clinical policy development at its first two meetings. Using these methods, the Panel (1) specified clearly the clinical questions to be addressed by the Guideline, which was achieved by identifying the "target patient" and listing the interventions and outcomes to be explored; (2) developed literature search strategies; (3) examined the literature critically; and (4) developed evidence tables based on the data extracted from the literature review.

The Panel divided into subcommittees to examine the data on interventions for otitis media with effusion. Each subcommittee determined the type of data that would be acceptable for inclusion in the evidence regarding the intervention. The subcommittees examining pharmaceutical or surgical interventions accepted only randomized, blinded, controlled studies for inclusion in the evidence for these interventions. For diagnostic interventions, the subcommittee reviewed the diagnostic gold standard pursuant to deciding which studies to include in the evidence. For control of environmental risk factors, the subcommittee looked for high-quality epidemiologic studies. For speech, language, and developmental outcomes, controlled studies that documented accurate diagnosis of otitis media with effusion in the target population of children were accepted for inclusion in the evidence.

The Panel also appointed subcommittees as necessary to review controversial areas, such as speech and language development and antibiotic treatment of otitis media with effusion. The report of the Subcommittee for Scientific Assessment, which reviewed the data on antibiotic treatment, is included in the Guideline Technical Report. Furthermore, the Panel and contractors guided and assisted those subcontracted to conduct the literature review (Children's Hospital of Pittsburgh), to perform the cost analysis (Lewin-VHI, Inc.), and to provide technical writing services (Children's Hospital of Pittsburgh).

The literature search was conducted using the on-line bibliographic data base of the National Library of Medicine and 10 specialized bibliographic data bases. The data bases searched, the search strategies, and the results are detailed in the Guideline Technical Report. Initial searches resulted in identification of 3,578 bibliographic citations, for which 1,362 abstracts were obtained and evaluated. Based on the initial review, 378 full-text articles were selected for data extraction using a nine-page form developed by the methodologist and Panel. More than 100 additional bibliographic citations were identified through review of literature reference lists, updated on-line searches, requests to professionals, and suggestions from experts. The interim panel chair also contacted numerous professional organizations to solicit unpublished data on this topic. The Guideline includes 158 references. In addition, the Panel sought information about otitis media with effusion by holding an Open Meeting that was announced in the Federal Register. Twelve oral testimonies were presented, eight of which were also written; additionally, twelve written testimonies were provided.

For each article considered for inclusion in the evidence, two different individuals extracted data, thus creating two records for each article in the data base. Because of the controversy regarding otitis media research at the University of Pittsburgh, all articles with a connection to the University of Pittsburgh were reviewed and data extracted by an independent professional. Literature review results were entered into a dBase (Ashton-Tate, Torrance, CA) data base with more than 720 fields. Entries in the data base were then corrected to eliminate any differences between extractions. The Panel reviewed the evidence in the data base and focused attention on randomized, blinded, controlled clinical studies wherever possible, although such evidence was not available in all areas of investigation. The Panel conducted an additional literature search and evaluation in the area of speech, language, and behavioral outcomes of otitis media with effusion. When possible, literature relevant to a given outcome was subjected to meta-analysis using FAST*PRO (Eddy and Hasselblad, 1992) to combine data by either Bayesian or hierarchical Bayesian techniques. To ensure against bias, meta-analysis of the data on antibiotic treatment of otitis media with effusion was reviewed by an independent expert.

During parts of each meeting, the Panel divided into subgroups to expedite the process of reviewing literature and making recommendations on diagnosis and the clinical interventions examined. Special subcommittees worked between Panel meetings to examine certain issues in greater depth, especially those of antibiotic treatment and of long-term outcomes. All deliberations of subgroups were brought back to the full Panel for discussion, revision, and approval. During Panel meetings, sessions were chaired by the co-chairs and the methodologist. The goal was to reach consensus on every decision. When consensus was not possible, votes were taken. If fewer than four Panel members disagreed with the decision, the decision was carried forward without comment. Many topics covered in the Guideline are controversial and remained so after review of the scientific evidence. Some Panel members strongly dissented from the majority opinion on individual recommendations and have written minority comments, included in an appendix to the Guideline Technical Report.

The paragraph below presents the grading system the Panel developed and summarizes the outcome of their deliberations regarding diagnostic and treatment interventions for otitis media with effusion in the target child. Of note is that the final recommendations are at least partially subjective, notwithstanding the level of objective scientific evidence for or against the recommendation. First, judgments about the quality of the science could not be fully objective; members of the Panel differed significantly in their individual judgments on issues such as long-term outcomes and the use of steroid and antibiotic medications, for example, even though all were evaluating the same data base. Second, the Panel occasionally linked weaker scientific evidence with strong theoretical arguments to construct a strong recommendation. An example is the recommendation regarding obtaining a hearing test before myringotomy and insertion of tympanostomy tubes. Each recommendation in the Guideline includes a statement about the basis for the Panel's decision.

## Panel Recommendations and Levels of Evidence

Although the Panel chose the target patient as a child age 1 through 3 years, the literature review showed that some of the recommendations could apply to older children. All the recommendations presented here are limited, however, to children with no craniofacial or neurologic abnormalities or sensory deficits (except as specifically noted in the recommendations) and who are healthy except for otitis media with effusion.

Individual recommendations were graded by the Panel as follows:

- Recommendations were made for interventions that the Panel took a stand for or against:
  - Strong recommendations were based on high-quality scientific evidence or, in the absence of high-quality scientific evidence, on strong Panel consensus.
  - Moderate recommendations were based on good-quality scientific evidence or, in the absence of good-quality scientific evidence, on expert opinion of the Panel.
  - Recommendations not otherwise specified were based on limited scientific evidence or, in the absence of scientific evidence, on expert opinion of the Panel.
- Clinical options were identified as interventions that the Panel failed to find compelling evidence for or against. Clinical options are interventions that a reasonable health care provider might or might not wish to implement in his or her practice.
- No recommendation was made when scientific evidence was lacking and there was no compelling reason to make an expert judgment.