# Back Cover

## Availability of Guidelines

For each clinical practice guideline developed under the sponsorship of the Agency for Health Care Policy and Research (AHCPR), several versions are produced to meet different needs.

The Guideline Technical Report contains complete supporting materials for the Clinical Practice Guideline, including background information, methodology, literature review, scientific evidence tables, and a comprehensive bibliography.

The Clinical Practice Guideline presents recommendations with brief supporting information, algorithms or flow charts, tables and figures, and pertinent references. The Quick Reference Guide for Clinicians is a distilled version of the Clinical Practice Guideline, with summary points for ready reference on a day-to-day basis.

The Consumer Version, available in English and Spanish, is an information booklet for the general public to increase patient knowledge and involvement in health care decisionmaking.

Guideline information also will be available for on-line retrieval through the National Library of Medicine, the National Technical Information Service, and some computer-based information systems of professional associations, nonprofit organizations, and commercial enterprises.

To order guideline products or to obtain further information on their availability, call the AHCPR Publications Clearinghouse toll-free at (800) 358-9295, or write to: AHCPR Publications Clearinghouse, P.O. Box 8547, Silver Spring, MD 20907.