# Acronyms

- ACE inhibitor
- Angiotensin-converting enzyme inhibitor
- AHCPR
- Agency for Health Care Policy and Research
- AV block
- Atrioventricular block
- BID
- Twice a day
- BUN
- Blood urea nitrogen
- CABG
- Coronary artery bypass graft
- CASS
- Coronary Artery Surgery Study
- CBC
- Complete blood count
- CONSENSUS
- Cooperative New Scandinavian Enalapril Survival Study
- COPD
- Chronic obstructive pulmonary disease
- ECG
- Electrocardiogram
- EF
- (Left-ventricular) Ejection fraction
- FDA
- Food and Drug Administration
- FFS
- Fee for service
- HMO
- Health maintenance organization
- HRQOL
- Health-related quality of life
- HYD/ISDN
- Hydralazine and isosorbide dinitrate
- MI
- Myocardial infarction
- NIH
- National Institutes of Health
- NHLBI
- National Heart, Lung, and Blood Institute
- NYHA
- New York Heart Association
- PET
- Positron emission tomography
- PTCA
- Percutaneous transluminal coronary angioplasty
- QD
- Once a day
- RCT
- Randomized controlled trial
- SAVE Trial
- Survival and Ventricular Enlargement Trial
- SOLVD
- Studies of Left-Ventricular Dysfunction
- TID
- Three times a day
- TSH
- Thyroid-stimulating hormone
- VHeFT
- Veterans Affairs Vasodilator Heart Failure Trial