# Glossary

- Ascites:
- Presence of free fluid within the peritoneal cavity.
- Atrial Fibrillation:
- An irregular heart rhythm produced by lack of coordinated action of the atrial pacemaker.
- Atrioventricular Block:
- Dissociation of the electrical impulses between the atrium and ventricle. Atrioventricular block generally results in a reduction in heart rate.
- Beta-Adrenergic Blockers:
- Pharmacological agents whose principal action is to reduce the effect of beta-adrenergic agonist agents (e.g., epinephrine) on the body's tissues.
- Bradyarrhythmias:
- Disturbances in cardiac rhythm that result in an abnormally slow heart rate.
- Cardiomegaly:
- Enlargement of the heart.
- Cardiomyopathy:
- Abnormality of the cardiac muscle.
- Cineangiography:
- Motion pictures of blood vessels obtained using radiographic imaging of an injected contrast medium.
- Coronary Angiography:
- A test in which a contrast medium is injected into the coronary arteries in order to determine coronary artery anatomy, including the presence, severity, and location of any obstruction.
- Dyspnea:
- The sensation of shortness of breath or difficulty breathing.
- Echocardiogram:
- A test that uses reflected sound waves to produce images of the heart to provide anatomical and functional information.
- (Left-Ventricular) Ejection Fraction:
- The proportion of blood present in the left ventricle at the end of ventricular diastole that is pumped through the aortic valve during systole.
- Heart Failure:
- A clinical syndrome or condition characterized by (1) signs and symptoms of intravascular and interstitial volume overload, including shortness of breath, rales, and edema, or (2) manifestations of inadequate tissue perfusion, such as fatigue or poor exercise tolerance.
- Left-Ventricular Diastolic Dysfunction:
- Inability of the left ventricle to fill normally during diastole, often due to decreased compliance of the ventricle walls. Ejection fraction is generally normal, but the elevated pressures required for ventricular filling can result in symptoms of pulmonary congestion. In addition, the reduced left-ventricular filling volume leads to lowered stroke volumes and symptoms of poor cardiac output.
- Left-Ventricular Systolic Dysfunction:
- Reduction in the pumping power of the left ventricle to the point where the left-ventricular ejection fraction is less than 35-40 percent, as opposed to the normal range of 50 percent or greater.
- Orthopnea:
- Dyspnea experienced when in the supine or prone position.
- Radionuclide Ventriculography:
- A test of ventricular structure and function in which images are produced through external detection of an intravascular radioactive tracer.
- Rales:
- Crackling or bubbling sounds heard during auscultation of the lungs. The presence of rales indicates that fluid has permeated the terminal bronchioles and alveoli, which can be due either to heart failure or to primary pulmonary disease, especially pneumonia.
- Tachycardia:
- Disturbances in cardiac rhythm that result in an abnormally rapid heart rate.