# Contributors

## Heart Failure Guideline Panel

- Marvin A. Konstam, MD, Co-chair
- Professor of Medicine
- Tufts University
- Director, Heart Failure and Cardiac Transplant Center
- New England Medical Center Hospitals
- Boston, Massachusetts

Dr. Konstam is professor of medicine and radiology at Tufts University School of Medicine. He is also director of the Adult Cardiac Catheterization Laboratory and director of the Heart Failure and Cardiac Transplant Center at New England Medical Center Hospitals, Boston. Dr. Konstam received his undergraduate and medical education at Columbia University. He received residency training in internal medicine and diagnostic radiology at the Massachusetts General Hospital and fellowship training in cardiology at the Brigham and Women's Hospital in Boston.

Dr. Konstam has been on the staff of New England Medical Center and Tufts University since 1981. His primary research interest is the pathophysiology and therapy of heart failure. He has published numerous original articles in these areas, primarily in the arenas of ventricular mechanics and function. He directed the Radionuclide-Ventricular Function Core Laboratory for the Studies of Left-Ventricular Dysfunction trials.

- Kathleen Dracup, DNSc, RN, FAAN, Co-chair
- Professor, School of Nursing
- University of California, Los Angeles
- Los Angeles, California

Dr. Dracup's nursing career includes more than 25 years of experience in cardiovascular nursing and university professorships. She received her master's degree from the University of California, Los Angeles (UCLA), and her doctoral degree from the University of California, San Francisco. The primary focus of Dr. Dracup's research has been the care of patients with cardiac disease and the effects of disease on the family. She has more than 100 publications in this area.

Dr. Dracup is professor in the UCLA School of Nursing and coeditor of the American Journal of Critical Care. She served as coeditor of Heart & Lung for more than a decade. She is currently chair of the National Heart, Lung, and Blood Institute (NHLBI) Working Group on Educational Strategies to Prevent Prehospital Delay in Patients at High Risk for Myocardial Infarction; she is also a member of several other national committees. Dr. Dracup is a fellow of the American Heart Association's Council of Cardiovascular Nursing. She has received numerous honors and awards, including a recent Fulbright Scholarship to conduct research and lecture in Australia during the 1994-95 academic year.

- Michael B. Bottorff, PharmD
- Associate Professor and Chairman Division of Clinical and Hospital Pharmacy
- University of Cincinnati College of Pharmacy
- Cincinnati, Ohio

Dr. Bottorff is associate professor and chairman, Division of Pharmacotherapy, University of Cincinnati. He received his Doctor of Pharmacy with high distinction from the University of Kentucky, Lexington, where, upon graduation in 1981, he became chief resident of the Albert B. Chandler Medical Center.

Dr. Bottorff is a member of several professional organizations, including the American College of Clinical Pharmacy of which he is currently chair, Abstract Review Committee for the Winter Meeting, and vice chair, Awards Committee; the American Pharmaceutical Association of which he was recently chairman, Clinical Section, Academy for Pharmaceutical Research and Science; and the American Society of Hospital Pharmacists. Dr. Bottorff serves on the editorial advisory board of the Journal of Applied Therapeutics and Pharmacotherapy and acts as a referee for 13 others.

- Neil H. Brooks, MD
- The American Academy of Family Physicians
- Rockville, Connecticut

Dr. Brooks is a 1968 graduate of the Hahnemann Medical College. He has been a practicing family physician in Rockville, Connecticut, since 1971. He is on the staff of Rockville General Hospital where he has chaired multiple committees and has been chair of the Department of Family Practice and chief of staff. He is the vice speaker of the American Academy of Family Physicians and serves on its Task Force on Clinical Policies for Patient Care. He is a past president of the Connecticut Academy of Family Physicians. His medical affiliations include the Connecticut State Medical Society, for which he is a member of the council, vice speaker of the House of Delegates, and a delegate to the American Medical Association. He is a founding member and president of Capital Area Independent Practice Associates (CIPA), a 1,600-physician independent practice association, and is on the Board of Directors of CHC, a 100,000-member health maintenance organization. He is also on the Medical Advisory Committee of Blue Cross/Blue Shield of Connecticut.

- Robert A. Dacey
- Consumer Representative
- Boulder, Colorado

Mr. Dacey is the past national president (1989-91) of The Mended Hearts, Inc., a 25,000-member, all-volunteer heart patient support group affiliated with the American Heart Association. Before heart surgery and a leg amputation, he was an advertising agency creative director, associate editor and publisher of Communication Arts magazine, and director of product research and development for Docere Corp., a health care and patient education publishing company. While in this position, Mr. Dacey directed the development of multimedia patient education programs and materials for orthopedic, cardiovascular, obstetrical and gynecologic, and dental implant procedures. His editorials and essays have appeared in Heartbeat, the official journal of The Mended Hearts, and Pulse, a publication of the Association of Heart Patients. His current interest is the development of patient information and education programs and materials that will help improve patient adherence to medical treatment.

- Sandra B. Dunbar, RN, DSN, FAAN
- Associate Professor, Emory University
- Nell Hodgson Woodruff School of Nursing
- Atlanta, Georgia

Dr. Dunbar is currently an associate professor and coordinator of the Critical Care Program in the Nell Hodgson Woodruff School of Nursing, Emory University, Atlanta. She has worked extensively with cardiac patients and their families in acute and outpatient clinical settings. Her current research is related to psychosocial outcomes from treatment of recurrent ventricular dysrhythmias.

- Anne B. Jackson, MA, RN
- American Association of Retired Persons National Legislative Council
- Queens Village, New York

Ms. Jackson, who lives in Sarasota, Florida, is a member of the National Legislative Council of the American Association of Retired Persons (AARP) and serves as chair of the Health and Future Generations Committee. Ms. Jackson has testified for AARP before the U.S. House of Representatives and the U.S. Senate. She is currently a commissioner for the Physician Payment Review Commission. Ms. Jackson was a professor at City University of New York in the Department of Nursing for 25 years. She also served in the positions of medical supervisor, head nurse, and staff nurse for the Veterans Affairs Hospital for 15 years.

- Mariell Jessup, MD
- Associate Professor of Medicine
- University of Pennsylvania School of Medicine
- Director, Heart Failure Unit Risk Reduction Center
- Philadelphia Heart Institute Presbyterian Medical Center
- Philadelphia, Pennsylvania

Dr. Jessup did her cardiovascular training at the Hospital of the University of Pennsylvania, where she met her mentor in heart failure research, Dr. Karl Weber. Since then, the focus of her clinical and research activities has been patients with chronic congestive heart failure and the evaluation of treatment options for these patients. As director of the Heart Failure Unit of the Philadelphia Heart Institute, she supervises a number of investigational drug protocols. Currently, she is exploring better methods of patient triage.

- Jerry C. Johnson, MD
- Associate Professor of Medicine
- University of Pennsylvania
- Chief, Geriatric Medicine Division
- Veterans Affairs Medical Center
- Philadelphia, Pennsylvania

Dr. Johnson is chief, Geriatric Medicine Division, Philadelphia Veterans Affairs Medical Center, and director, Geriatric Medicine Fellowship Training Program, University of Pennsylvania. After training in internal medicine, Dr. Johnson was a Robert Wood Johnson Clinical Scholar before focusing on geriatrics. He is now a nationally recognized clinician and educator with extensive experience in caring for complex elderly patients with acute and chronic medical problems. He has conducted several studies of neuropsychiatric complications of acute medical problems and of quality-of-life outcomes of chronic care interventions. Dr. Johnson is now engaged in clinical studies of elderly patients with heart disease as part of the University of Pennsylvania's Clinical Research Center on Psychiatric Illness.

- Robert H. Jones, MD
- Mary and Deryl Hart Professor of Surgery
- Duke University Medical Center
- Durham, North Carolina

Dr. Jones is a cardiac surgeon with a special interest in coronary artery bypass grafting in patients with poor ventricular function and congestive heart failure. His prior research interests have focused on developing radionuclide techniques to noninvasively detect and characterize coronary artery disease. He served as project director for development of Unstable Angina: Diagnosis and Management. Clinical Practice Guideline No. 10. The guideline was sponsored by AHCPR and the National Institutes of Health (NIH).

- Robert J. Luchi, MD
- Chief, Geriatrics Section Director, Huffington Center on Aging
- Baylor College of Medicine
- ACOS Geriatrics and Extended Care
- Veterans Affairs Medical Center
- Houston, Texas

Dr. Luchi is director, Roy M. and Phyllis Gough Huffington Center on Aging at Baylor College of Medicine, and professor and chief, Geriatrics Section, Department of Medicine. He is the associate chief of staff for geriatrics and extended care at the Houston Veterans Affairs Medical Center. He received his MD degree in 1952 and was trained in internal medicine and cardiology at the University of Pennsylvania School of Medicine. Dr. Luchi is a member of the American, Central, and Southern Societies for Clinical Investigation, and a fellow of the American College of Physicians (ACP), American Geriatrics Society (AGS), Gerontological Society of America (GSA), and American College of Cardiology (ACC). He has served on national committees for the American Heart Association, ACC, the Department of Veterans Affairs, and the National Board of Medical Examiners. His major research interests include congestive heart failure in the elderly and unstable angina. He has published more than 95 scientific articles, a number of which are related to congestive heart failure.

- Barry M. Massie, MD
- Professor of Medicine
- University of California, San Francisco
- Director, Hypertension Clinic Director, Coronary Care Unit
- Veterans Affairs Medical Center
- San Francisco, California

Dr. Massie is a clinical and research cardiologist who serves as professor of medicine at the University of California, San Francisco, and Director of the Coronary Care Unit and Hypertension Clinic at the San Francisco Veterans Affairs Medical Center. His clinical research interests include the pathophysiology of heart failure, with a focus on the mechanism of exercise intolerance, and the investigation of new therapeutic agents. He also directs a research group investigating heart metabolism and hypertensive heart disease. Dr. Massie has published more than 160 articles and book chapters, mainly dealing with heart failure and hypertension. He serves on the editorial boards of several journals, including the Journal of the American College of Cardiology and Heart Failure. He is a consultant to the FDA in the evaluation of new cardiac medications.

- Bertram Pitt, MD
- Professor of Internal Medicine Associate Chairman of Academic and Industrial Programs Department of Internal Medicine
- University of Michigan Medical Center
- Ann Arbor, Michigan

Dr. Pitt is professor of internal medicine and associate chairman for academic and industrial programs in the Department of Internal Medicine, University of Michigan School of Medicine, Ann Arbor, Michigan. He received his medical degree from the University of Basel, Switzerland.

Dr. Pitt has published 245 articles in scientific journals. He is a member of the American Physiological Society-Circulation Group, the American Federation for Clinical Research, the International Society for Heart Research, and the American Heart Association. He is also president of the Michigan Chapter of the American College of Cardiology and a fellow of the American College of Cardiology. Honors he has received include Bronze Award, American Heart Association-Circulation Group; Haile Selassie Lecturer, British Heart Foundation; and Outstanding Cardiology Staff.

- Eric A. Rose, MD
- Chief, Cardiothoracic Surgery
- Columbia Presbyterian Medical Center
- New York, New York

Dr. Rose is professor of surgery and chief of the Division of Cardiothoracic Surgery at Columbia University. His interest in the surgical management of heart failure entails clinical practice, teaching, and research in the areas of reparative coronary artery and valvular procedures and cardiac replacement therapies. The latter include transplantation, mechanical cardiac assistance, and cross-species transplantation. He is the current president of the International Society for Heart and Lung Transplantation.

- Lewis J. Rubin, MD
- Professor of Physiology and Professor of Medicine
- University of Maryland School of Medicine
- Baltimore, Maryland

Dr. Rubin is professor of medicine and head of the Division of Pulmonary and Critical Care Medicine at the University of Maryland School of Medicine. His major research interests include disorders of the pulmonary circulation and cardiopulmonary interactions. He received the Vascular Disease Academic Award from NHLBI, the National Institutes of Health (NIH). Dr. Rubin serves on advisory committees for NIH, the American Heart Association, and the American Lung Association.

- Richard F. Wright, MD
- Research Director, Pacific Heart Institute
- Assistant Clinical Professor, University of California
- Los Angeles, California

Dr. Wright received his medical degree from Harvard Medical School. After an internship at the University of Southern California, he returned to Harvard, where he received internal medicine and cardiology training at the Brigham and Women's Hospital. In addition to postdoctoral research at Harvard, Dr. Wright has received research training at the Ames Research Center, National Aeronautics and Space Administration, and the Oak Ridge National Laboratory, Atomic Energy Commission. He is presently in the clinical practice of cardiology, with special expertise and ongoing research in the management of heart failure and in cardiopulmonary resuscitation. Dr. Wright has been president of the Los Angeles Society of Echocardiography and is research director at Pacific Heart Institute, assistant clinical professor at UCLA School of Medicine, and chairman of the Cardiology Section at St. John's Hospital and Health Center, Santa Monica, California.

## Peer and Pilot Reviewers[a]

- William H. Barry, MD
- Salt Lake City, Utah
- Darla F. Bonham
- The Mended Hearts, Inc.
- Dallas, Texas
- Richard W. Campbell, MD
- American College of Physicians
- Indianapolis, Indiana
- Clifton R. Cleaveland, MD
- American College of Physicians
- Chattanooga, Tennessee
- Barbara J. Drew, RN, PhD
- University of California School of Nursing
- San Francisco, California
- Gerald F. Fletcher, MD
- Emory University School of Medicine
- Atlanta, Georgia
- Erika S. Froelicher, RN, PhD
- University of California School of Nursing
- San Francisco, California
- Richard Gorlin, MD
- The Mount Sinai Medical Center
- New York, New York
- John F. Hagaman, MD
- Cardiology Associates of Princeton
- Princeton, New Jersey
- Mairead L. Hickey, PhD, RN
- Brigham and Women's Hospital
- Boston, Massachusetts
- William B. Hood, Jr., MD
- University of Rochester Medical Center
- Rochester, New York
- Michael J. Horan, MD, ScM
- National Heart, Lung, and Blood Institute
- Bethesda, Maryland
- June Howland-Gradman, MSN, RN
- Emergency Nurses Association
- Park Ridge, Illinois
- Randal F. Hundley, MD
- Cardiac Diagnostic Clinic
- Little Rock, Arkansas
- Pamela Kidd, RN, PhD
- Emergency Nurses Association
- Park Ridge, Illinois
- Ronald Dee Legako, MD
- Canyon Park Family Physicians, Inc.
- Edmond, Oklahoma
- Donald F. Leon, MD
- Georgetown University Medical Center
- Washington, DC
- Patrick E. McBride, MD, MPH
- University of Wisconsin Medical School
- Madison, Wisconsin
- Debra K. Moser, DNSc, RN
- UCLA School of Nursing
- Los Angeles, California
- John B. O'Connell, MD
- The University of Mississippi Medical Center
- Jackson, Mississippi
- Milton Packer, MD
- College of Physicians and Surgeons of Columbia University
- New York, New York
- Richard B. Perry, MD
- American College of Physicians
- Potomac, Maryland
- Deeb Salem, MD
- New England Medical Center
- Boston, Massachusetts
- Robert J. Schlant, MD
- Emory University School of Medicine
- Atlanta, Georgia
- Edmund H. Sonnenblick, MD
- Albert Einstein College of Medicine
- Bronx, New York
- Stephen J. Spann, MD
- The University of Texas Medical Branch at Galveston
- Kathryn Taubert, MD
- American Heart Association
- Dallas, Texas
- George E. Thibault, MD
- Harvard Medical School
- Boston, Massachusetts
- David R. Witmer, PharmD
- American Society of Hospital Pharmacists
- Bethesda, Maryland
- James B. Young, MD
- Baylor College of Medicine
- Houston, Texas

Being listed in this section does not necessarily imply endorsement of the guideline.

## AHCPR Staff

- Francis Chesley, MD
- Project officer
- Carole Hudgings, PhD
- Acting director
- Office of the Forum for Quality and Effectiveness in Health Care
- William N. LeVee
- Managing editor
- Valna Montgomery, MSW
- Product manager