# References

1. Thom T.(National Heart, Lung, and Blood Institute).Letter to: David C. Hadorn. Written communication: 1993;Apr 12.
2. Levit KR, Lazenby HC, Cowan CA, et al. National health expenditures. Health Care Fin Rev 1991. 1990;13:29-54.
3. National Center for Health Statistics. Detailed diagnoses and procedures, National Hospital Discharge Survey. Vital and health statistics, Series 13, No. 113. Hyattsville (MD): The Center. 1992. DHHS publication. 1990;No. 92-1774.
4. National Center for Health Statistics. National Ambulatory Medical Care Survey, 1989 summary. Vital and health statistics, Series 13, No. 110. Hyattsville (MD):The Center. 1992. DHHS publication No. 92-1771.
5. National Center for Health Statistics. Discharges from nursing homes: 1985; National Nursing Home Survey. Vital and health statistics. Series 13, No. 103. Hyattsville (MD): The Center; 1990. DHHS publication No. (PHS) 90-1764.
6. Daley J, Jencks S, Draper D, et al. Predicting hospital-associated mortality for Medicare patients. A method for patients with stroke, pneumonia, acute myocardial infarction, and congestive heart failure. JAMA. 1988;Dec 23-30;260:3617-24. [pmid: 3057251].
7. Iezzoni LI, Ash AS, Coffman G, et al. Admission and mid-stay MedisGroups scores as predictors of death within 30 days of hospital admission. Am J Public Health. 1991;81:74-8. [pmid: 1983920]. [pmcid: 1404930].
8. Keeler EB, Kahn KL, Draper D, et al. Changes in sickness at admission following the introduction of the prospective payment system. JAMA. 1990 Oct 17;264:1962-8. [pmid: 2120475].
9. Bounous EP, Mark DB, Pollock BG, et al. Surgical survival benefits for coronary disease patients with left-ventricular dysfunction. Circulation. 1988 Sep;78(3 Pt 2):I-151 to I-157.
10. CONSENSUS Trial Study Group. Effects of enalapril on mortality in severe congestive heart failure. N Engl J Med. 1987;316:1429-35. [pmid: 2883575].
11. Kahn KL, Rogers WH, Rubenstein LV, et al. Measuring quality of care with explicit process criteria before and after implementation of the DRG-based prospective payment system. JAMA. 1990;264:1969-73. [pmid: 2120476].
12. Kosecoff J, Kahn KL, Rogers WH, et al. Prospective payment system and the impairment at discharge: the "quicker and sicker" story revisited. JAMA. 1990 Oct 17;264:1980-3. [pmid: 2214063].
13. Retchin SM, Brown B. Elderly patients with congestive heart failure under prepaid care. Am J Med. 1991;90:236-42. [pmid: 1996594].
14. Fleg JL, Hinton PC, Lakatta EG, et al. Physician utilization of laboratory procedures to monitor outpatients with congestive heart failure. Arch Intern Med. 1989;149:393-6. [pmid: 2916884].
15. Pfeffer MA, Braunwald E, Moy LA, et al. Effect of captopril on mortality and morbidity in patients with left-ventricular dysfunction after myocardial infarction: results of the survival and ventricular enlargement trial. N Engl J Med. 1992;327:669-77.
16. SOLVD Investigators. Effect of enalapril on mortality and the development of heart failure in asymptomatic patients with reduced left-ventricular ejection fractions. N Engl J Med. 1992;327:685-91. [pmid: 1463530].
17. Cohn JN, Archibald DG, Ziesche S, et al. Effect of vasodilator therapy on mortality in chronic congestive heart failure: results of a Veterans Administration Cooperative Study. N Engl J Med. 1986;314:1547-52. [pmid: 3520315].
18. SOLVD Investigators. Effect of enalapril on survival in patients with reduced left-ventricular ejection fractions and congestive heart failure. N Engl J Med. 1991 Aug 1;325:293-302. [pmid: 2057034].
19. Cohn JN, Johnson G, Ziesche S, et al. A comparison of enalapril with hydralazine-isosorbide dinitrate in the treatment of chronic congestive heart failure. N Engl J Med. 1991 Aug;325:303-10. [pmid: 2057035].
20. Chalmers I.Evaluating the effects of care during pregnancy and childbirth. In: Chalmers I, Enkin M, Keirse MJ, editors. Effective care in pregnancy and childbirth.Oxford: Oxford University Press;1989.Chapter 1.
21. Chalmers TC, Smith H Jr, Blackburn B, et al. A method for assessing the quality of a randomized control trial. Controlled Clin Trials. 1981;2:31-49. [pmid: 7261638].
22. Detsky AS, Naylor CD, O'Rourke K, et al. Incorporating variations in the quality of individual randomized trials into meta-analysis. J Clin Epidemiol. 1992;45:255-65. [pmid: 1569422].
23. Feinstein AR. Epidemiologic analyses of causation: the unlearned scientific lessons of randomized trials. J Clin Epidemiol. 1989;42:481-502. [pmid: 2661727].
24. Liberati A, Himel HN, Chalmers TC. A quality assessment of randomized control trials of primary treatment of breast cancer. J Clin Oncol. 1986;4:942-51. [pmid: 3711962].
25. Swedberg K, Held P, Kjekshus J, et al. Effects of the early administration of enalapril on mortality in patients with acute myocardial infarction: results of the Cooperative New Scandinavian Enalapril Survival Study II (CONSENSUS II). N Engl J Med. 1992;327:678-84. [pmid: 1495520].
26. Marantz PR, Tobin JN, Wassertheil-Smoller S, et al. The relationship between left-ventricular systolic function and congestive heart failure diagnosed by clinical criteria. Circulation. 1988;77:607-12. [pmid: 3342491].
27. Mattleman SJ, Hakki A, Iskandrian AS, et al. Reliability of bedside evaluation in determining left-ventricular function: correlation with left-ventricular ejection fraction determined by radionuclide ventriculography. J Am Coll Cardiol. 1983;1:417-20. [pmid: 6826952].
28. Harlan WR, Oberman A, Grimm R, et al. Chronic congestive heart failure in coronary artery disease: clinical criteria. Ann Intern Med. 1977;86:133-8. [pmid: 835934].
29. Echeverria HH, Bilsker MS, Myerburg RJ, et al. Congestive heart failure: echocardiographic insights. Am J Med. 1983;75:750-5. [pmid: 6638044].
30. Dougherty AH, Naccarelli GV, Gray EL, et al. Congestive heart failure with normal systolic function. Am J Cardiol. 1984;54:778-82. [pmid: 6486027].
31. Stevenson LW, Perloff JK. The limited reliability of physical signs for estimating hemodynamics in chronic heart failure. JAMA. 1989 Feb 10;261:884-8. [pmid: 2913385].
32. Chakko CS, Woska D, Martinez H, et al. Clinical, radiographic, and hemodynamic correlations in chronic congestive heart failure: conflicting results may lead to inappropriate care. Am J Med. 1991 Mar;90:353-9. [pmid: 1825901].
33. Gadsbøll N, Høilund-Carlsen PF, Nielsen GG, et al. Symptoms and signs of heart failure in patients with myocardial infarction: reproducibility and relationship to chest x-ray, radionuclide ventriculography and right heart catheterization. Eur Heart J. 1989;10:1017-28. [pmid: 2591393].
34. Ishmail AA, Wing S, Ferguson J, et al. Interobserver agreement by auscultation in the presence of a third heart sound in patients with congestive heart failure. Chest. 1987;91:870-3. [pmid: 3581934].
35. Stapleton JF, Segal JP, Harvey WP. The electrocardiogram of myocardiopathy. Prog Cardiovasc Dis. 1970 Nov;13:217-39. [pmid: 5528789].
36. Arnsdorf MF, Bump TE. Management of arrhythmias in heart failure. Cardiol Clin. 1989 Feb;7:145-69. [pmid: 2650869].
37. Francis GS. Development of arrhythmias in the patient with congestive heart failure: pathophysiology, prevalence, and prognosis. Am J Cardiol. 1986;57:3-7.
38. Fletcher D, Archibald D, Orndorff J, et al. Dysrhythmias on short term Holter as an independent predictor of mortality in congestive heart failure [abstract]. J Am Coll Cardiol. 1986 Feb;7.
39. Olshausen KV, Stienen U, Schwarz F, et al. Long-term prognostic significance of ventricular arrhythmias in idiopathic dilated cardiomyopathy. Am J Cardiol. 1988;61:146-51. [pmid: 3337004].
40. Cleland JG, Dargie HJ, Wilson JT. Clinical, haemodynamic, and antiarrhythmic effects of long term treatment with amiodarone of patients with heart failure. Br Heart J. 1987;57:436-45. [pmid: 3297121]. [pmcid: 1277198].
41. Neri R, Mestroni L, Salvi A, et al. Ventricular arrhythmias in dilated cardiomyopathy: efficacy of amiodarone. Am Heart J. 1987 Mar;113:707-15. [pmid: 3825860].
42. Nicklas JM, Mickelson JK, Das SK, et al. Prospective, randomized, double-blind, placebo-controlled trial of low dose amiodarone in patients with severe heart failure and frequent ventricular ectopy [abstract]. Circulation. 1988;78(4 Pt 2):II-27.
43. Nicklas JM, McKenna WJ, Stewart RA, et al. Prospective, double-blind, placebo-controlled trial of low-dose amiodarone in patients with severe heart failure and asymptomatic frequent ventricular ectopy. Am Heart J. 1991 Oct;122:1016-21. [pmid: 1927852].
44. Simonton CA, Daly PA, Kereiakes D, et al. Survival in severe left-ventricular failure treated with the new nonglycosidic, nonsympathomimetic oral inotropic agents. Chest. 1987;92:118-23. [pmid: 2954776].
45. Bigger JT Jr. Why patients with congestive heart failure die: arrhythmias and sudden cardiac death. Circulation. 1987;75(5 Pt 2):IV-28 to IV-35.
46. Chakko CS, Gheorghiade M. Ventricular arrhythmias in severe heart failure: incidence, significance, and effectiveness of antiarrhythmic therapy. Am Heart J. 1985 Mar;109:497-504. [pmid: 3976476].
47. Franciosa JA. Why patients with heart failure die: hemodynamic and functional determinants of survival. Circulation. 1987;75(5 Pt 2):IV-20 to IV-27.
48. Francis GS. Sudden death and heart failure. Curr Opin Cardiol. 1990;5:291-4.
49. Ikegawa T, Chino M, Hasegawa H, et al. Prognostic significance of 24-hour ambulatory electrocardiographic monitoring in patients with dilative cardiomyopathy: a prospective study. Clin Cardiol. 1987 Feb;10:78-82. [pmid: 3815927].
50. Suyama A, Anan T, Araki H, et al. Prevalence of ventricular tachycardia in patients with different underlying heart diseases: a study by Holter ECG monitoring. Am Heart J. 1986 Jul;112:44-51. [pmid: 3728286].
51. Wilson JR, Schwartz JS, Sutton MS, et al. Prognosis in severe heart failure: relation to hemodynamic measurements and ventricular ectopic activity. J Am Coll Cardiol. 1983 Sep;2:403-10. [pmid: 6192158].
52. Podrid PJ. Can antiarrhythmic drugs cause arrhythmias?. J Clin Pharmacol 1984. 24:313-9.
53. Podrid PJ. Aggravation of ventricular arrhythmia. A drug-induced complication. Drugs. 1985;29(Suppl 4):33-44. [pmid: 3924550].
54. Poser R, Lombardi F, Podrid P, et al. Aggravation of induced arrhythmias with antiarrhythmic drugs during electrophysiological testing [abstract]. J Am Coll Cardiol. 1983;1.
55. Ruskin JN, McGovern B, Garan H, et al. Antiarrhythmic drugs: a possible cause of out-of-hospital cardiac arrest. N Engl J Med. 1983;309:1302-6. [pmid: 6633588].
56. Torres V, Flowers D, Somberg JC. The arrhythmogenicity of antiarrhythmic agents. Am Heart J. 1985;109:1090-7. [pmid: 3993517].
57. Velebit V, Podrid P, Lown B, et al. Aggravation and provocation of ventricular arrhythmias by antiarrhythmic drugs. Circulation. 1982;65:886-94. [pmid: 6176355].
58. Morganroth J, Horowitz LN. Flecainide: its proarrhythmic effect and expected changes on the surface electrocardiogram. Am J Cardiol. 1984;53:89B-94B. [pmid: 6695821].
59. Oetgen WJ, Tibbits PA, Abt MEO, et al. Clinical electrophysiologic assessment of oral flecainide acetate for recurrent ventricular tachycardia: evidence for exacerbation of electrical instability. Am J Cardiol. 1983;52:746-50. [pmid: 6624666].
60. Winkle RA, Mason JW, Griffin JC, et al. Malignant ventricular tachyarrhythmias associated with the use of encainide. Am Heart J. 1981;102:857-64. [pmid: 6795909].
61. The Cardiac Arrhythmia Suppression Trial II Investigators. Effect of the antiarrhythmic agent moricizine on survival after myocardial infarction. N Engl J Med 1992. 327:227-33.
62. The Cardiac Arrhythmia Suppression Trial (CAST) Investigators. Preliminary report: effect of encainide and flecainide on mortality in a randomized trial of arrhythmia suppression after myocardial infarction. N Engl J Med. 1989;321:406-12. [pmid: 2473403].
63. Rich MW, Freedland KE. Effect of DRGs on three-month readmission rate of geriatric patients with congestive heart failure. Am J Public Health. 1988;78:680-2. [pmid: 2835909]. [pmcid: 1350282].
64. Vinson JM, Rich MW, Sperry JC, et al. Early readmission of elderly patients with congestive heart failure. J Am Geriatr Soc. 1990;38:1290-5. [pmid: 2254567].
65. Gooding J, Jette AM. Hospital readmissions among the elderly. J Am Geriatr Soc 1985 Sep. 33:595-601.
66. Rosenberg S. Patient education leads to better care for heart patients. HSMHA Health Rep. 1971;86:793-802. [pmid: 5129289]. [pmcid: 1937170].
67. Perlman LV, Isenberg EL, Donovan I, et al. Public health nurses and the prevention of recurrences of congestive heart failure. Geriatrics. 1969 Sep;24:82-9. [pmid: 5811750].
68. Acquatella H, Rodriguez-Salas LA, Gomez-Mancebo JR. Doppler echocardiography in dilated and restrictive cardiomyopathies. Cardiol Clin. 1990 May;8:349-67. [pmid: 2189566].
69. Aguirre FV, Pearson AC, Lewen MK, et al. Usefulness of Doppler echocardiography in the diagnosis of congestive heart failure. Am J Cardiol. 1989 May 1;63:1098-102. [pmid: 2705380].
70. Aronow WS, Ahn C, Kronzon I. Prognosis of congestive heart failure in elderly patients with normal versus abnormal left-ventricular systolic function associated with coronary artery disease. Am J Cardiol. 1990 Nov 15;66:1257-9. [pmid: 2239734].
71. Eagle KA, Quertermous T, Singer DE, et al. Left-ventricular ejection fraction: physician estimates compared with gated blood pool scan measurements. Arch Intern Med. 1988 Apr;148:882-5. [pmid: 3355308].
72. Gadsbøll N, Høilund-Carlsen PF, Nielsen GG, et al. Interobserver agreement and accuracy of bedside estimation of right and left-ventricular ejection fraction in acute myocardial infarction. Am J Cardiol. 1989;63:1301-7. [pmid: 2729103].
73. Soufer R, Wohlgelernter D, Vita NA, et al. Intact systolic left-ventricular function in clinical congestive heart failure. Am J Cardiol. 1985;55:1032-6. [pmid: 3984863].
74. Strauss RH, Stevenson LW, Dadourian BA, et al. Predictability of mitral regurgitation detected by Doppler echocardiography in patients referred for cardiac transplantation. Am J Cardiol. 1987 Apr;59:892-4. [pmid: 3548306].
75. Wong WF, Gold S, Fukuyama O, et al. Diastolic dysfunction in elderly patients with congestive heart failure. Am J Cardiol. 1989 June 15;63:1526-8. [pmid: 2729143].
76. Folland ED, Parisi AF, Moynihan PF, et al. Assessment of left-ventricular ejection fraction and volumes by real-time, two-dimensional echocardiography. A comparison of cineangiographic and radionuclide techniques. Circulation. 1979 Oct;60:760-6. [pmid: 476879].
77. Stamm RB, Carabello BA, Mayers DL, et al. Two-dimensional echocardiographic measurement of left-ventricular ejection fraction: prospective analysis of what constitutes an adequate determination. Am Heart J. 1982 Jul;104:136-44. [pmid: 7090969].
78. Albin G, Rahko PS. Comparison of echocardiographic quantitation of left-ventricular ejection fraction to radionuclide angiography in patients with regional wall motion abnormalities. Am J Cardiol. 1990 Apr 15;65:1031-2. [pmid: 2327339].
79. Chen Y, Sherrid MV, Dwyer EM Jr. Value of two-dimensional echocardiography in evaluating coronary artery disease: a randomized blinded analysis. J Am Coll Cardiol. 1985 Apr;5:911-7. [pmid: 3973293].
80. Diaz RA, Nihoyannopoulos P, Athanassopoulos G, et al. Usefulness of echocardiography to differentiate dilated cardiomyopathy from coronary-induced congestive heart failure. Am J Cardiol. 1991 Nov 1;68:1224-7. [pmid: 1951085].
81. Ghali JK, Kadakia S, Cooper RS, et al. Bedside diagnosis of preserved versus impaired left-ventricular systolic function in heart failure. Am J Cardiol. 1991 May 1;67:1002-6. [pmid: 2018002].
82. Medina R, Panidis IP, Morganroth J, et al. The value of echocardiographic regional wall motion abnormalities in detecting coronary artery disease in patients with or without a dilated left ventricle. Am Heart J. 1985;109:799-803. [pmid: 3157304].
83. Wallis DE, O'Connell JB, Henkin RE, et al. Segmental wall motion abnormalities in dilated cardiomyopathy: a common finding and good prognostic sign. J Am Coll Cardiol. 1984 Oct;4:674-9. [pmid: 6481009].
84. Greenberg JM, Murphy JH, Okada RD, et al. Value and limitations of radionuclide angiography in determining the cause of reduced left-ventricular ejection fraction: comparison of idiopathic dilated cardiomyopathy and coronary artery disease. Am J Cardiol. 1985 Feb;55:541-4. [pmid: 4038571].
85. Bonow RO, Udelson JE. Left ventricular diastolic dysfunction as a cause of congestive heart failure: mechanisms and management. Ann Intern Med. 1992;117:502-10. [pmid: 1503353].
86. Cuocolo A, Sax FL, Brush JE, et al. Left ventricular hypertrophy and impaired diastolic filling in essential hypertension. Diastolic mechanisms for systolic dysfunction during exercise. Circulation. 1990;81:978-86. [pmid: 2137735].
87. Fouad F, Slominiski M, Slominski M, Tarazi RC. Left ventricular diastolic function in hypertension: relation to left ventricular mass and systolic function. J Am Coll Cardiol. 1984;3:1500-6. [pmid: 6232306].
88. Fouad FM, Tarazi RC, Gallagher JH, et al. Abnormal left ventricular relaxation in hypertensive patients. Clin Sci. 1980;59(Suppl 6):4114-45.
89. Inouye I, Massie B, Loge D, et al. Abnormal left ventricular filling: an early finding in mild to moderate systemic hypertension. Am J Cardiol. 1985;53:120-6.
90. Cuocolo A, Sax FL, Brush JE, et al. Impaired diastolic function in hypertensive patients without left ventricular hypertrophy [abstract]. J Nucl Med. 1989;30.
91. Demakis JG, Proskey A, Rahimtoola SH, et al. The natural course of alcoholic cardiomyopathy. Ann Intern Med. 1974 Mar;80:293-7. [pmid: 4273902].
92. Mølgaard H, Kristensen BO, Baandrup U. Importance of abstention from alcohol in alcoholic heart disease. Int J Cardiol. 1990;26:373-5.
93. Regan TJ. Alcohol and the cardiovascular system. JAMA. 1990 Jul 18;264:377-81. [pmid: 2194048].
94. Dracup K, Walden JA, Stevenson LW, et al. Quality of life in patients with advanced heart failure. J Heart Lung Transplant. 1992;2:273-9.
95. Rideout E, Montemuro M. Hope, morale and adaptation in patients with chronic heart failure. J Adv Nurs. 1986;11:429-38. [pmid: 3638318].
96. Julian D. Cardiology. London: Bailliere Tindall. 1988.
97. On bedresting in heart failure [editorial]. Lancet. 1990;336(8721):975-6. [pmid: 1977010].
98. Convertino VA, Goldwater DJ, Sandler H. Bedrest-induced peak VO2 reduction associated with age, gender, and aerobic capacity. Aviat Space Environ Med. 1986 Jan;57:17-22. [pmid: 3942565].
99. Convertino VA, Doerr DF, Mathes KL, et al. Changes in volume, muscle compartment, and compliance of the lower extremities in man following 30 days of exposure to simulated microgravity. Aviat Space Environ Med. 1989 Jul;60:653-8. [pmid: 2764848].
100. Saltin B, Blomqvist G, Mitchell JH, et al. Response to exercise after bed rest and after training. Circulation. 1968;38(5 Suppl):VII-1 to VII-78.
101. Dudley GA, Duvoisin MR, Convertino VA, et al. Alterations of the in vivo torque-velocity relationship of human skeletal muscle following 30 days exposure to simulated microgravity. Aviat Space Environ Med. 1989;60:659-63. [pmid: 2764849].
102. Coats AJ, Adamopoulos S, Meyer TE, et al. Effects of physical training in chronic heart failure. Lancet. 1990;335(8681):63-6. [pmid: 1967416].
103. Kellermann JJ, Shemesh J, Fisman EZ, et al. Arm exercise training in the rehabilitation of patients with impaired ventricular function and heart failure. Cardiology. 1990;77:130-8. [pmid: 2397489].
104. Maskin CS, Reddy HK, Gulanick M, et al. Exercise training in chronic heart failure: improvement in cardiac performance and maximum oxygen uptake [abstract]. Circulation. 1986 Oct;74(4 Pt 2):II-310.
105. Meyer TE, Casadei B, Coats AJ, et al. Angiotensin-converting enzyme inhibition and physical training in heart failure. J Intern Med. 1991;230:407-13. [pmid: 1658183].
106. Sullivan MJ, Higginbotham MB, Cobb FR. Exercise training in patients with chronic heart failure delays ventilatory anaerobic threshold and improves submaximal exercise performance. Circulation. 1989;79:324-9. [pmid: 2914350].
107. Coats AJ, Adamopoulos S, Radaelli A, et al. Controlled trial of physical training in chronic heart failure. Exercise performance, hemodynamics, ventilation, and autonomic function. Circulation. 1992;85:2119-31. [pmid: 1591831].
108. Arvan S. Exercise performance of the high risk acute myocardial infarction patient after cardiac rehabilitation. Am J Cardiol. 1988 Aug 1;62:197-201. [pmid: 3400598].
109. Jugdutt BI, Michorowski BL, Kappagoda CT. Exercise training after anterior Q wave myocardial infarction: importance of regional left-ventricular function and topography. J Am Coll Cardiol. 1988 Aug;12:362-72. [pmid: 3392328].
110. Dubach P, Froelicher VF. Cardiac rehabilitation for heart failure patients. Cardiology. 1989;76:368-73. [pmid: 2688876].
111. Sullivan MJ, Higginbotham MB, Cobb FR. Exercise training in patients with severe left-ventricular dysfunction: hemodynamic and metabolic effects. Circulation. 1988;78:506-15. [pmid: 3409495].
112. Sullivan MJ, Cobb FR. The anaerobic threshold in chronic heart failure. Relation to blood lactate, ventilatory basis, reproducibility, and response to exercise training. Circulation. 1990 Jan;81(1 Suppl):II-47 to II-58.
113. AMA Council on Foods and Nutrition.Sodium-restricted diets: the rationale, complications, and practical aspects of their use.JAMA 1954 Nov 13;156:1081-3.
114. Dahl L. Salt and hypertension. Am J Clin Nutr. 1972;25:231-44. [pmid: 5009786].
115. Dyckner T, Wester P. Salt and water balance in congestive heart failure. Acta Med Scand. 1986;707(Suppl):27-31.
116. Healy MA, Aslam M. Dietary sodium and cardiac oedema. Nurs Times. 1984 Oct;80:41-5.
117. Hopkins BE, Taylor RR. Sodium restriction in cardiac failure: a survey of physicians' attitudes and practice. Med J Aust. 1972 Feb;1:370-1. [pmid: 5027799].
118. Kris-Etherton PM, Kisloff L, Kassouf RA, et al. Teaching principles and cost of sodium-restricted diets. J Am Diet Assoc. 1982;80:50-4.
119. Snively WD Jr, Beshear DR, Roberts KT. Sodium-restricted diet: review and current status. Nurs Forum. 1974;13:59-66. [pmid: 4494642].
120. Snively WD Jr, Roberts KT, Beshear DR. The sodium-restricted diet revisited. J Indiana State Med Assoc. 1974;67:1067-76. [pmid: 4477575].
121. Tobin JR. The treatment of congestive heart failure: digitalis glycosides are still the primary mode of therapy. Arch Intern Med. 1978 Mar;138:453-4. [pmid: 629640].
122. Tucker RM, Van Den Berg CJ, Knox FG. Diuretics: role of sodium balance. Mayo Clin Proc. 1980;55:261-6. [pmid: 7359953].
123. Conway N. Hemodynamic effects of ethyl alcohol in coronary heart disease. Am Heart J. 1968 Oct;76:581-2. [pmid: 5676326].
124. Gould L, Zahir M, DeMartino A, et al. Cardiac effects of a cocktail. JAMA. 1971 Dec 20;218:1799-802. [pmid: 5171442].
125. Packer M, Carver JR, Rodeheffer RJ, et al. Effect of oral milrinone on mortality in severe chronic heart failure. N Engl J Med. 1991 Nov;325:1468-75. [pmid: 1944425].
126. Kannel WB. Epidemiological aspects of heart failure. Cardiol Clin. 1989;7:1-9.
127. Sugrue DD, Rodeheffer RJ, Codd MB, et al. The clinical course of idiopathic dilated cardiomyopathy: a population-based study. Ann Intern Med. 1992;117:117-23. [pmid: 1605426].
128. Dracup K, Guzy PM, Taylor SE, et al. Cardiopulmonary resuscitation (CPR) training: for family members of high-risk cardiac patients. Arch Intern Med. 1986;146:1757-61. [pmid: 3753116].
129. Ghali JK, Kadakia S, Cooper R, et al. Precipitating factors leading to decompensation of heart failure. Traits among urban blacks. Arch Intern Med. 1988 Sep;148:2013-6. [pmid: 3046541].
130. Mullen PD, Green LW, Persinger GS. Clinical trials of patient education for chronic conditions: a comparative meta-analysis of intervention types. Prev Med. 1985;14:753-81. [pmid: 2418436].
131. Mullen PD, Mains DA, Velez R. A meta-analysis of controlled trials of cardiac patient education. Patient Educ Couns. 1992;19:143-62. [pmid: 1299819].
132. Küpper AJ, Fintelman H, Huige MC, et al. Cross-over comparison of the fixed combination of hydrochlorothiazide and triamterene and the free combination of furosemide and triamterene in the maintenance treatment of congestive heart failure. Eur J Clin Pharmacol. 1986;30:341-3. [pmid: 3732372].
133. Whight C, Morgan T, Carney S, et al. Diuretics, cardiac failure and potassium depletion: a rational approach. Med J Aust. 1974 Dec 7;2:831-3. [pmid: 4217884].
134. Edmonds CJ, Jasani B. Total-body potassium in hypertensive patients during prolonged diuretic therapy. Lancet. 1972 Jul 1;2(766):8-12. [pmid: 4113653].
135. Cody RJ. Management of refractory congestive heart failure. Am J Cardiol. 1992 Jun 4;69:141G-149G. [pmid: 1626487].
136. Bussmann WD, Storger H, Hadler D, et al. Long-term treatment of severe chronic heart failure with captopril: a double-blind, randomized, placebo-controlled, long-term study. J Cardiovasc Pharmacol. 1987;9(Suppl 2):S50-60. [pmid: 2441202].
137. The Captopril-Digoxin Multicenter Research Group. A placebo-controlled trial of captopril in refractory chronic congestive heart failure. J Am Coll Cardiol. 1983;2:755-63. [pmid: 6350401].
138. Franciosa JA, Wilen MM, Jordan RA. Effects of enalapril, a new angiotensin-converting enzyme inhibitor, in a controlled trial in heart failure. J Am Coll Cardiol. 1985 Jan;5:101-7. [pmid: 2981088].
139. Jennings G, Kiat H, Nelson L, et al. Enalapril for severe congestive heart failure: a double-blind study. Med J Aust. 1984 Nov 24;141:723-6. [pmid: 6094995].
140. Kleber FX, Niemöller L, Fischer M, et al. Influence of severity of heart failure on the efficacy of angiotensin-converting enzyme inhibition. Am J Cardiol. 1991;68:121D-126D. [pmid: 1746416].
141. Magnani B, Magelli C. Captopril in mild heart failure: preliminary observations of a long-term, double-blind, placebo-controlled multicentre trial. Postgrad Med J. 1986;62(Suppl 1):153-8. [pmid: 3534852].
142. McGrath BP, Arnolda L, Matthews PG, et al. Controlled trial of enalapril in congestive cardiac failure. Br Heart J. 1985;54:405-14. [pmid: 2996575]. [pmcid: 481919].
143. Remes J, Nikander P, Rehnberg S, et al. Enalapril in chronic heart failure, a double-blind placebo-controlled study. Ann Clin Res. 1986;18:124-8. [pmid: 3017174].
144. Sharpe DN, Murphy J, Coxon R, et al. Enalapril in patients with chronic heart failure: a placebo-controlled, randomized, double-blind study. Circulation. 1984;70:271-8. [pmid: 6329547].
145. Chalmers JP, West MJ, Cyran J, et al. Placebo-controlled study of lisinopril in congestive heart failure: a multicentre study. J Cardiovasc Pharmacol. 1987;9(Suppl 3):S89-97. [pmid: 2442560].
146. Lewis GR. Comparison of lisinopril versus placebo for congestive heart failure. Am J Cardiol. 1989 Feb 21;63:12D-16D. [pmid: 2537560].
147. Riegger GA. The effects of ACE inhibitors on exercise capacity in the treatment of congestive heart failure. J Cardiovasc Pharmacol. 1990;15(Suppl 2):S41-6.
148. Riegger GA. Effects of quinapril on exercise tolerance in patients with mild to moderate heart failure. Eur Heart J. 1991;12:705-11. [pmid: 1830551].
149. Brogden RN, Todd PA, Sorkin EM. Captopril: an update of its pharmacodynamic and pharmacokinetic properties, and therapeutic use in hypertension and congestive heart failure. Drugs. 1988 Nov;36:540-600. [pmid: 3063499].
150. Cleland JG, Dargie HJ. Heart failure, renal function, and angiotensin converting enzyme inhibitors. Kidney Int. 1987;31(Suppl 20):S220-8.
151. Cleland JG, Gillen G, Dargie HJ. The effects of furosemide and angiotensin-converting enzyme inhibitors and their combination on cardiac and renal hemodynamics in heart failure. Eur Heart J. 1988;9:132-41. [pmid: 2832173].
152. Crantock L, Prentice R, Powell L. Cholestatic jaundice associated with captopril therapy. J Gastroenterol Hepatol. 1991;6:528-30. [pmid: 1932674].
153. Frank GJ. The safety of ACE inhibitors for the treatment of hypertension and congestive heart failure. Cardiology. 1989;76(Suppl 2):56-67. [pmid: 2670222].
154. Hasford J, Bussmann WD, Delius W, et al. First dose hypotension with enalapril and prazosin in congestive heart failure. Int J Cardiol. 1991;31:287-94. [pmid: 1879978].
155. Kjekshus J, Swedberg K. Tolerability of enalapril in congestive heart failure. Am J Cardiol. 1988;62:67A-72A. [pmid: 2839020].
156. O'Neill CJ, Bowes SG, Sullens CM, et al. Evaluation of the safety of enalapril in the treatment of heart failure in the very old. Eur J Clin Pharmacol. 1988;35:143-50. [pmid: 2847929].
157. Packer M. Identification of risk factors predisposing to the development of functional renal insufficiency during treatment with converting-enzyme inhibitors in chronic heart failure. Cardiology. 1989;76(Suppl 2):50-5. [pmid: 2670221].
158. Suki WN. Renal hemodynamic consequences of angiotensin-converting enzyme inhibition in congestive heart failure. Arch Intern Med. 1989 Mar;149:669-73. [pmid: 2537612].
159. Warner NJ, Rush JE, Keegan ME. Tolerability of enalapril in congestive heart failure. Am J Cardiol. 1989 Feb;63:33D-37D. [pmid: 2537564].
160. Giles TD, Katz R, Sullivan JM, et al. Short- and long-acting angiotensin-converting enzyme inhibitors: a randomized trial of lisinopril versus captopril in the treatment of congestive heart failure. J Am Coll Cardiol. 1989 May;13:1240-7. [pmid: 2539403].
161. Packer M, Gheorghiade M, Young D, et al. Withdrawal of digoxin from patients with chronic heart failure treated with angiotensin-converting-enzyme inhibitors. N Engl J Med. 1993;329:1-7. [pmid: 8505940].
162. Jaeschke R, Oxman AD, Guyatt GH. To what extent do congestive heart failure patients in sinus rhythm benefit from digoxin therapy? A systematic overview and meta-analysis. Am J Med. 1990;88:279-86. [pmid: 2178412].
163. The Captopril-Digoxin Multicenter Research Group. Comparative effects of therapy with captopril and digoxin in patients with mild to moderate heart failure. JAMA. 1988 Jan 22/29;259:539-44. [pmid: 2447297].
164. DiBianco R, Shabetai R, Kostuk W, et al. A comparison of oral milrinone, digoxin, and their combination in the treatment of patients with chronic heart failure. N Engl J Med. 1989;320:677-83. [pmid: 2646536].
165. Marcus FI. Pharmacokinetic interactions between digoxin and other drugs. J Am Coll Cardiol. 1985;5(Suppl A):82A-90A. [pmid: 2985676].
166. Elkayam U. Tolerance to organic nitrates: evidence, mechanisms, clinical relevance, and strategies for prevention. Ann Intern Med. 1991;114:667-77. [pmid: 2003715].
167. Kyrle PA, Korninger C, Gössinger H, et al. Prevention of arterial and pulmonary embolism by oral anticoagulants in patients with dilated cardiomyopathy. Thromb Haemost. 1985;54:521-3. [pmid: 4082088].
168. Sherman DG, Dyken ML, Fisher M, et al. Antithrombotic therapy for cerebrovascular disorders. Chest. 1989 Feb;95(Suppl 2):1405-555.
169. Falk RH. A plea for a clinical trial of anticoagulation in dilated cardiomyopathy [editorial]. Am J Cardiol. 1990 Apr 1;65:14-5. [pmid: 2294677].
170. Ciaccheri M, Castelli G, Cecchi F, et al. Lack of correlation between intracavitary thrombosis detected by cross sectional echocardiography and systemic emboli in patients with dilated cardiomyopathy. Br Heart J. 1989 Jul;62:26-9. [pmid: 2757871]. [pmcid: 1216726].
171. Fuster V, Gersh BJ, Giuliani ER, et al. The natural history of idiopathic dilated cardiomyopathy. Am J Cardiol. 1981 Mar;47:525-31. [pmid: 7468489].
172. Gottdiener JS, Gay JA, Van Voorhees L, et al. Frequency and embolic potential of left-ventricular thrombus in dilated cardiomyopathy: assessment by 2-dimensional echocardiography. Am J Cardiol. 1983;52:1281-5. [pmid: 6650417].
173. Roberts WC, Siegel RJ, McManus BM. Idiopathic dilated cardiomyopathy: analysis of 152 necropsy patients. Am J Cardiol. 1987;60:1340-55. [pmid: 3687784].
174. The Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators. The effect of low-dose warfarin on the risk of stroke in patients with nonrheumatic atrial fibrillation. N Engl J Med. 1990;323:1505-11. [pmid: 2233931].
175. Petersen P, Boysen G, Godtfredsen J, et al. Placebo-controlled, randomised trial of warfarin and aspirin for prevention of thromboembolic complications in chronic atrial fibrillation. The Copenhagen AFASAK study. Lancet. 1989 Jan 28;1(8631):175-9. [pmid: 2563096].
176. The Stroke Prevention in Atrial Fibrillation Investigators. Stroke prevention in atrial fibrillation study. Final results. Circulation. 1991;84:527-39. [pmid: 1860198].
177. The Stroke Prevention in Atrial Fibrillation Investigators. Predictors of thromboembolism in atrial fibrillation: I. Clinical features of patients at risk. Ann Intern Med. 1992 Jan 1;116:1-12. [pmid: 1727091].
178. Anderson JL, Lutz JR, Gilbert EM, et al. A randomized trial of low-dose beta-blockade therapy for idiopathic dilated cardiomyopathy. Am J Cardiol. 1985;55:471-5. [pmid: 2857523].
179. Cucchini F, Compostella L, Papalia D, et al. Chronic treatment of dilated cardiomyopathy by beta-blocking drugs. Long term clinical and hemodynamic evaluation. G Ital Cardiol. 1988 Oct;18:835-42. [pmid: 2907743].
180. Currie PJ, Kelly MJ, McKenzie A, et al. Oral beta-adrenergic blockade with metoprolol in chronic severe dilated cardiomyopathy. J Am Coll Cardiol. 1984 Jan;3:203-9. [pmid: 6140277].
181. Fisher ML, Gottlieb SS, Hamilton B, et al. Beneficial effects of metoprolol in CHF associated with coronary artery disease [abstract]. Circulation. 1991;84(4)(Suppl II):II-312.
182. Ikram H, Fitzpatrick MA. Beta blockade for dilated cardiomyopathy: the evidence against therapeutic benefit. Eur Heart J. 1983;4(Suppl A):179-80. [pmid: 6220894].
183. Swedberg K, Hjalmarson A, Waagstein F, et al. Adverse effects of beta-blockade withdrawal in patients with congestive cardiomyopathy. Br Heart J. 1980;44:134-42. [pmid: 6107091]. [pmcid: 482372].
184. Verdin A, Wikstrand J, Wilhelmsson C, et al. Left-ventricular function and beta-blockade in chronic ischaemic heart failure. Double-blind, cross-over study of propranolol and penbutolol using non-invasive techniques. Br Heart J. 1980;44:101-7. [pmid: 7000099]. [pmcid: 482367].
185. Waagstein F, Bristow MR, Swedberg K, et al. Beneficial effects of metoprolol in idiopathic dilated cardiomyopathy. Lancet. 1993 Dec 11;342(8885):1441-6. [pmid: 7902479].
186. Weber KT, Likoff MJ, McCarthy D. Low-dose beta blockade in the treatment of chronic cardiac failure. Am Heart J. 1982;104:877-9. [pmid: 6127026].
187. Yokota Y, Nomura H, Kawai H, et al. Effects of long-term beta-blockade (metoprolol) therapy in patients with dilated cardiomyopathy. Jpn Circ J. 1991 Apr;55:343-55. [pmid: 2046141].
188. Engelmeier RS, O'Connell JB, Walsh R, et al. Improvement in symptoms and exercise tolerance by metoprolol in patients with dilated cardiomyopathy: a double-blind, randomized, placebo-controlled trial. Circulation. 1985 Sep;72:536-46. [pmid: 3893793].
189. Cleland JG, Henderson E, McLenachan J, et al. Effect of captopril, an angiotensin-converting enzyme inhibitor, in patients with angina pectoris and heart failure. J Am Coll Cardiol. 1991 Mar 1;17:733-9. [pmid: 1993795].
190. Kannel WB, Cupples A. Epidemiology and risk profile of cardiac failure. Cardiovasc Drugs Ther. 1988 Nov;2:387-95. [pmid: 3154646].
191. Bulkley BH. The cardiomyopathies. Hosp Pract. 1984;19:59-73.
192. Pasternac A, Bourassa MG. Pathogenesis of chest pain in patients with cardiomyopathies and normal coronary arteries. Int J Cardiol. 1983 Jun;3:273-80. [pmid: 6347913].
193. Kotler TS, Diamond GA. Exercise thallium-201 scintigraphy in the diagnosis and prognosis of coronary artery disease. Ann Intern Med. 1990;113:684-702. [pmid: 2221649].
194. Murphy ML, Hultgren HN, Detre K, et al. Treatment of chronic stable angina: a preliminary report of the randomized Veterans Administration Cooperative Study. N Engl J Med. 1977;297:621-7. [pmid: 331107].
195. Varnauskas E. Twelve-year followup of survival in the randomized European Coronary Surgery Study. N Engl J Med. 1988;319:332-7. [pmid: 3260659].
196. Alderman EL, Fisher LD, Litwin P, et al. Results of coronary artery surgery in patients with poor left ventricular function (CASS). Circulation. 1983 Oct;68:785-95. [pmid: 6352078].
197. Faulkner SL, Stoney WS, Alford WC, et al. Ischemic cardiomyopathy: medical versus surgical treatment. J Thorac Cardiovasc Surg. 1977 Jul;74:77-82. [pmid: 301591].
198. Manley JC, King JF, Zeft HJ, et al. The "bad" left ventricle: results of coronary surgery and effect on late survival. J Thorac Cardiovasc Surg. 1976 Dec;72:841-8. [pmid: 994534].
199. Pigott JD, Kouchoukos NT, Oberman A, et al. Late results of medical and surgical therapy for patients with coronary artery disease and depressed ejection fraction [abstract]. Circulation. 1982;66(Suppl 2):II-220.
200. Vliestra RE, Assad-Morell JL, Frye RL, et al. Survival predictors in coronary artery disease. Medical and surgical comparisons. Mayo Clin Proc. 1977;52:85-90. [pmid: 305511].
201. Hammermeister KE, DeRouen TA, Dodge HT. Comparison of survival of medically and surgically treated coronary disease patients in Seattle Heart Watch: a nonrandomized study. Circulation. 1982;65(7 Pt 2):53-9. [pmid: 6979432].
202. Yatteau RF, Peter RH, Behar VS, et al. Ischemic cardiomyopathy: the myopathy of coronary artery disease. Am J Cardiol. 1974;34:520-5. [pmid: 4278154].
203. Califf RM, Harrell FE Jr, Lee KL, et al. The evolution of medical and surgical therapy for coronary artery disease. A 15-year perspective. JAMA. 1989 Apr 14;261:2077-86. [pmid: 2784512].
204. Coronary Artery Surgery Study (CASS) Principal Investigators and Their Associates. Coronary Artery Surgery Study (CASS): a randomized trial of coronary artery bypass surgery. Survival data. Circulation. 1983;68:939-50. [pmid: 6137292].
205. Muhlbaier LH, Pryor DB, Rankin JS, et al. Observational comparison of event-free survival with medical and surgical therapy in patients with coronary artery disease. 20 years of follow-up. Circulation. 1992;86(5 Suppl):II-198 to II-204.
206. Akins CW, Pohost GM, DeSanctis RW, et al. Selection of angina-free patients with severe left-ventricular dysfunction for myocardial revascularization. Am J Cardiol. 1980 Oct;46:695-700. [pmid: 7416028].
207. Luu M, Stevenson LW, Brunken RC, et al. Delayed recovery of revascularized myocardium after referral for cardiac transplantation. Am Heart J. 1990 Mar;119:668-70. [pmid: 2309608].
208. Naunheim KS, Dean PA, Fiore DA, et al. Cardiac surgery in the octogenarian. Eur J Cardiothorac Surg. 1990;4:130-5. [pmid: 2334552].
209. Spencer FC, Green GE, Tice DA, et al. Coronary artery bypass grafts for congestive heart failure: a report of experiences with 40 patients. J Thorac Cardiovasc Surg. 1971;62:529-42. [pmid: 5093810].
210. Christakis GT, Ivanov J, Weisel R, et al. The changing pattern of coronary artery bypass surgery. Circulation. 1989 Sep;80(3 Pt 1):I151-61. [pmid: 2788531].
211. Hannan EL, Kilburn H Jr, O'Donnell JF, et al. Adult open heart surgery in New York State. An analysis of risk factors and hospital mortality rates. JAMA. 1990 Dec 5;264:2768-74. [pmid: 2232064].
212. Higgins TL, Estafanous FG, Loop FD, et al. Stratification of morbidity and mortality outcome by preoperative risk factors in coronary artery bypass patients: a clinical severity score. JAMA. 1992 May 6;267:2344-8. [pmid: 1564774].
213. Williams SV, Nash DB, Goldfarb N. Differences in mortality from coronary artery bypass graft surgery at five teaching hospitals. JAMA. 1991 Aug 14;226:810-15.
214. Cohen M, Charney R, Hershman R, et al. Reversal of chronic ischemic myocardial dysfunction after transluminal coronary angioplasty. J Am Coll Cardiol. 1988 Nov;12:1193-8. [pmid: 2971701].
215. Hartzler GO, Rutherford BD, McConahay DR, et al. "High-risk" percutaneous transluminal coronary angioplasty. Am J Cardiol. 1988 May;61:33G-37G. [pmid: 2966564].
216. Klein HH, Neuhaus KL. Delayed improvement of myocardial function after recanalization of a chronic coronary occlusion in a patient with intractable heart failure. Eur Heart J. 1990;11:280-6. [pmid: 2318230].
217. Reinfeld HB, Samet P, Hildner FJ. Resolution of congestive failure, mitral regurgitation, and angina after percutaneous transluminal coronary angioplasty of triple vessel disease. Cathet Cardiovasc Diagn. 1985;11:273-7. [pmid: 3160478].
218. Serota H, Deligonul U, Lee W, et al. Predictors of cardiac survival after percutaneous transluminal coronary angioplasty in patients with severe left-ventricular dysfunction. Am J Cardiol. 1991 Feb 15;67:367-72. [pmid: 1994660].
219. Taylor GJ, Rabinovich E, Mikell FL, et al. Percutaneous transluminal coronary angioplasty as palliation for patients considered poor surgical candidates. Am Heart J. 1986 May;111:840-4. [pmid: 2422911].
220. Kiat H, Berman DS, Maddahi J, et al. Late reversibility of tomographic myocardial thallium-201 defects: an accurate marker of myocardial viability. J Am Coll Cardiol. 1988 Dec;12:1456-63. [pmid: 3263995].
221. Brunken R, Schwaiger M, Grover-McKay M, et al. Positron emission tomography detects tissue metabolic activity in myocardial segments with persistent thallium perfusion defects. J Am Coll Cardiol. 1987;10:557-67. [pmid: 3497966].
222. Mudge GH, Goldstein S, Addonizio LJ, et al. 24th Bethesda conference: Cardiac transplantation. Task Force 3: Recipient guidelines/prioritization. J Am Coll Cardiol. 1993 Jul;22:21-31. [pmid: 8509544].
223. Goldman L, Hashimoto D, Cook EF, et al. Comparative reproducibility and validity of systems for assessing cardiovascular functional class: advantages of a new specific activity scale. Circulation. 1981;64:1227-34. [pmid: 7296795].
224. Guyatt GH, Nogradi S, Halcrow S, et al. Development and testing of a new measure of health status for clinical trials in heart failure. J Gen Intern Med. 1989;4:101-7. [pmid: 2709167].
225. Rector TS. Outcome assessment: functional status measures as therapeutic endpoints for heart failure. Top Hosp Pharm Manage. 1990;10:37-43. [pmid: 10128563].
226. Tandon PK, Stander H, Schwarz RP Jr. Analysis of quality of life data from a randomized, placebo-controlled heart-failure trial. J Clin Epidemiol. 1989;42:955-62. [pmid: 2681547].
227. Creager MA, Faxon DP, Halperin JL, et al. Determinants of clinical response and survival in patients with congestive heart failure treated with captopril. Am Heart J. 1982 Nov;104:1147-54. [pmid: 6291360].
228. Nelson GR, Cohn PF, Gorlin R. Prognosis in medically-treated coronary artery disease: influence of ejection fraction compared to other parameters. Circulation. 1975 Sep;52:408-12. [pmid: 1157237].
229. Schwarz F, Mall G, Zebe H, et al. Determinants of survival in patients with congestive cardiomyopathy: quantitative morphologic findings and left-ventricular hemodynamics. Circulation. 1984;70:923-8. [pmid: 6499148].
230. Cohn JN, Johnson GR, Shabetai R, et al. Ejection fraction, peak exercise oxygen consumption, cardiothoracic ratio, ventricular arrhythmias, and plasma norepinephrine as determinants of prognosis in heart failure. Circulation. 1993;87(Suppl VI):VI-5 to VI-16.
231. Cintron G, Johnson G, Francis G, et al. Prognostic significance of serial changes in left ventricular ejection fraction in patients with congestive heart failure. Circulation. 1993;87(Suppl VI):VI-17 to VI-23.
232. Franciosa JA, Jordan RA, Wilen MM, et al. Minoxidil in patients with chronic left heart failure: contrasting hemodynamic and clinical effects in a controlled trial. Circulation. 1984 Jul;70:63-8. [pmid: 6373050].
233. Baim D, McDowell A, Cherniles J, et al. Evaluation of a new bipyridine inotropic agent-milrinone-in patients with severe congestive heart failure. N Engl J Med. 1983;309:748-56. [pmid: 6888453].
234. Simonton CA, Chatterjee K, Cody RJ, et al. Milrinone in congestive heart failure: acute and chronic hemodynamic and clinical evaluation. J Am Coll Cardiol. 1985;6:453-9. [pmid: 4019930].
235. Packer M, Carver JR, Rodeheffer RJ, et al. Effect of oral milrinone on mortality in severe chronic heart failure. N Engl J Med. 1991;325:1468-75. [pmid: 1944425].
236. Narahara KA, The Western Enoximone Study Group and the REFLECT Investigators. Spontaneous variability of ventricular function in patients with chronic heart failure. Am J Med. 1993;95:513-8. [pmid: 8238068].
237. Wackers FJT, Berger HJ, Johnstone DE, et al. Multiple gated cardiac blood pool imaging for left ventricular ejection fraction: validation of the technique and assessment of variability. Am J Cardiol. 1979 Jun;43:1159-66. [pmid: 443176].