# Executive Summary

Heart failure is a serious condition affecting an estimated 2 million Americans and resulting in average mortality rates of 10 percent at 1 year and 50 percent after 5 years. In addition, quality of life is reduced for many heart failure patients, who often experience physical symptoms and reduced functional status. Because the incidence of heart failure rises substantially beyond age 65, the prevalence of this condition is likely to increase as the population ages.

Heart failure also places a significant economic burden on society, consuming more than $10 billion in health care expenditures each year. More than $7 billion was spent on the 1 million hospitalizations that took place for this condition in 1990. The Heart Failure Guideline Panel believes that many of these hospitalizations could have been prevented by improved outpatient care. In addition, many of the tests and treatments currently provided to heart failure patients are of dubious value. In other cases, appropriate services are underutilized.

This guideline describes the range of diagnostic and management strategies that the guideline panel considers appropriate for heart failure patients with left-ventricular systolic dysfunction. This guideline addresses only briefly management of patients whose heart failure has occurred despite normal ventricular systolic performance and does not address management of patients with surgically correctable valvular disease. This guideline contains recommendations that are applicable for use in inpatient and outpatient settings but does not consider interventions that can be applied only in the hospital setting (e.g., cardiac assist devices). The recommendations described in the guideline are based where possible on evidence obtained from extensive literature reviews. Where evidence was lacking, recommendations were based on the consensus opinion of the panel, as formulated after receiving input and suggestions from dozens of consultants around the country.

This guideline is intended for use by a broad range of health care practitioners, including family physicians, internists, cardiologists, cardiac surgeons, clinical nurse specialists, nurse practitioners, and physician assistants. The guideline panel recommends that consultation be obtained whenever practitioners find that management is difficult or complicated, or when invasive management is contemplated.

This Executive Summary describes the most significant recommendations contained in the guideline. To place these recommendations within a logical framework, this summary is organized around a clinical algorithm (Attachment). The algorithm is designed both to depict the scope of the guideline and to provide assistance with decisionmaking strategies for patients and practitioners on a case-by-case basis. The guideline's key recommendations are organized as annotations to this algorithm, which combines four additional, more focused algorithms presented as figures in the guideline text.

Figure 5. Clinical Algorithm for Evaluation and Care of Patients With Heart Failure

Note: See Executive Summary for annotation. LV = left-ventricular, MI = myocardial infarction.

The recommendations are presented here in very abbreviated form. Readers should refer to the guideline text for supporting discussion, including citations and levels of evidence for each recommendation. The first topic addressed below is the prevention of clinical heart failure in patients with asymptomatic left-ventricular systolic dysfunction. Because these patients do not yet manifest heart failure, a prevention node is not included in the management algorithm.

## Prevention in Asymptomatic Patients

Asymptomatic patients who are found to have moderately or severely reduced left-ventricular systolic function (ejection fraction [EF] <35-40 percent) should be treated with an angiotensin-converting enzyme (ACE) inhibitor to reduce the chance of developing clinical heart failure.

Probably the largest number of such patients will be those who have recently sustained a myocardial infarction (MI). For this reason, EF should be determined in most patients following an MI unless they are at low risk for significant systolic dysfunction-that is, unless they meet all of the following criteria:

- No previous MI.
- Inferior infarction.
- Relatively small increase in cardiac enzymes (i.e., <2-4 times normal).
- No Q waves develop on electrocardiogram (ECG).
- Uncomplicated clinical course (e.g., no arrhythmias or hypotension).

Other asymptomatic patients without MI's may be found to have reduced EF on evaluation of heart murmurs or cardiomegaly. These patients should also be treated with ACE inhibitors.

## Patient Evaluation

### Symptoms of Heart Failure

All patients who complain of paroxysmal nocturnal dyspnea, orthopnea, or new-onset dyspnea on exertion should undergo evaluation for heart failure unless history and physical examination clearly indicate a noncardiac cause for their symptoms, such as severe pulmonary disease.

### Initial Evaluation

The physical examination can provide important information about the etiology of patients' symptoms and about appropriate initial treatment. However, physical signs are not highly sensitive for detecting heart failure.

Patients with symptoms that are highly suggestive of heart failure should undergo echocardiography or radionuclide ventriculography to measure left-ventricular EF (see below) even if physical signs of heart failure are absent.

### Evaluation for Alternative Diagnoses

Practitioners should perform a chest x-ray; ECG; complete blood count (CBC); serum electrolytes, serum creatinine, serum albumin, liver function tests; and urinalysis for all patients with suspected or clinically evident heart failure. A T4 and thyroid-stimulating hormone (TSH) level should also be checked in all patients over the age of 65 with heart failure and no obvious etiology, and in patients who have atrial fibrillation or other signs or symptoms of thyroid disease.

### Need for Hospital Management

Presence or suspicion of heart failure and any of the following findings usually indicates a need for hospitalization:

- Clinical or ECG evidence of acute myocardial ischemia.
- Pulmonary edema or severe respiratory distress.
- Oxygen saturation below 90 percent (not due to pulmonary disease).
- Severe complicating medical illness (e.g., pneumonia).
- Anasarca.
- Symptomatic hypotension or syncope.
- Heart failure refractory to outpatient therapy.
- Inadequate social support for safe outpatient management.

Patients with heart failure should be discharged from the hospital only when:

- Symptoms of heart failure have been adequately controlled.
- All reversible causes of morbidity have been treated or stabilized.
- Patients and caregivers have been educated about medications, diet, activity and exercise recommendations, and symptoms of worsening heart failure.
- Adequate outpatient support and followup care have been arranged.

Patients who have been hospitalized for heart failure should be seen or contacted within 1 week of discharge to make sure that they are stable in the outpatient setting and to check their understanding of and compliance with the treatment plan.

### Assessment of Volume Overload and Initial Therapy

During initial evaluation, the clinician should determine whether the patient manifests symptoms or signs of volume overload.

Symptoms of volume overload include orthopnea, paroxysmal nocturnal dyspnea, and dyspnea on exertion. Signs of volume overload include pulmonary rales, a third heart sound, jugular venous distension, hepatic engorgement, ascites, peripheral edema, and pulmonary vascular congestion or pulmonary edema on chest x-ray.

Patients with heart failure and signs of significant volume overload should be started immediately on a diuretic. Patients with mild volume overload can be managed adequately on thiazide diuretics, whereas those with more severe volume overload should be started on a loop diuretic.

### Assessment of Left-Ventricular Function

Patients with suspected heart failure should undergo echocardiography or radionuclide ventriculography to measure EF (if information about left-ventricular function is not available from previous tests).

Most patients with heart failure will have EF less than 35-40 percent. Patients with EF of 40 percent or greater may still have heart failure on the basis of valvular disease or diastolic dysfunction.

## Patient Management

### Patient and Family Counseling and Education

After a diagnosis of heart failure is established, all patients should be counseled regarding the nature of heart failure, drug regimens, dietary restrictions, symptoms of worsening heart failure, what to do if these symptoms occur, and prognosis.

It is vital that patients understand their disease and be involved in developing the plan for their care. In addition, family members and other responsible caregivers should be included in counseling and decisionmaking sessions.

Regular exercise such as walking or cycling should be encouraged for all patients with stable heart failure.

There is insufficient evidence at this time to recommend the routine use of formal rehabilitation programs for patients with heart failure, although patients who are anxious about exercising on their own or are dyspneic at a low work level may benefit from such programs.

Dietary sodium should be restricted to as close to 2 grams per day as possible. In no case should sodium intake exceed 3 grams daily. Alcohol use should be discouraged. Patients who drink alcohol should be advised to consume no more than one drink per day. One drink equals a glass of beer or wine, or a mixed drink or cocktail containing no more than 1 ounce of alcohol.

It is vital that patients receive accurate information concerning prognosis in order to make decisions and plans for the future. Practitioners should discuss patients' desires regarding resuscitation, and all patients should be encouraged to complete a durable power of attorney for health care or another form of advance directive.

Because noncompliance is a major cause of morbidity and unnecessary hospital admissions in heart failure, educational programs or support groups should be a routine part of the care of patients with heart failure.

Practitioners should be aware of the problem of noncompliance and its causes and should discuss the importance of compliance at followup visits and assist patients in removing barriers to compliance (e.g., cost, side effects, or complexity of the medical regimen).

### Initial Pharmacological Management

As noted above under Assessment of Volume Overload and Initial Therapy, diuretics should be started immediately when patients present with symptoms or signs of volume overload.

Patients with heart failure due to left-ventricular systolic dysfunction should be given a trial of ACE inhibitors unless specific contraindications exist: (1) history of intolerance or adverse reactions to these agents, (2) serum potassium greater than 5.5 mEq/L that cannot be reduced, or (3) symptomatic hypotension. Patients with systolic blood pressure less than 90 mmHg have a higher risk of complications and should be managed by a physician experienced in utilizing ACE inhibitors in such patients. Caution and close monitoring are also required for patients who have a serum creatinine greater than 3.0 mg/dL or an estimated creatinine clearance of less than 30 mL/min; half the usual dose should be used in this setting.

ACE inhibitors may be considered as sole therapy in the subset of heart failure patients who present with fatigue or mild dyspnea on exertion and who do not have any other signs or symptoms of volume overload. Diuretics should be added if symptoms persist.

Isosorbide dinitrate and hydralazine is an appropriate alternative in patients with contraindications or intolerance to ACE inhibitors.

Digoxin can prevent clinical deterioration in patients with heart failure due to left-ventricular systolic dysfunction, although its effect on exercise tolerance and mortality is not clear. Digoxin should be used routinely in patients with severe heart failure and should be added to the medical regimen of patients with mild or moderate heart failure who remain symptomatic after optimal management with ACE inhibitors and diuretics.

Patients with mild-to-moderate heart failure who become asymptomatic on optimal doses of ACE inhibitors and diuretics do not require digoxin.

Routine anticoagulation is not recommended. Patients with a history of systemic or pulmonary embolism, recent atrial fibrillation, or mobile left-ventricular thrombi should be anticoagulated to a prothrombin time ratio of 1.2-1.8 times each individual laboratory control time (International Normalization Ratio 2.0-3.0).

## Evaluation of Patients for Revascularization

Coronary artery disease is currently the most common cause of heart failure in the United States, and some heart failure patients may benefit from revascularization.

### Contraindications to Revascularization

There are no absolute contraindications to revascularization except if the patient refuses surgery or is unable to give informed consent. However, a number of factors may preclude intervention or raise the risk above any expected benefit:

- Patient is unwilling to consider surgery.
- Severe comorbid diseases, especially renal failure, pulmonary disease, or cerebrovascular disease (e.g., severe stroke).
- Very low EF (i.e., <20 percent).
- Illnesses that imply a limited life expectancy less than or equal to 1 year, including advanced cancer, severe lung or liver disease, chronic renal disease, advanced diabetes mellitus, and advanced collagen vascular disease.
- Technical factors, including previous myocardial revascularization or other cardiac procedure, inadequate vascular conduit, history of chest irradiation, and diffuse distal coronary artery atherosclerosis.

### Patient Counseling and Decision

Patients without contraindication to revascularization should be advised of the possibility of revascularization, including its potential benefits and harms.

Three parameters are important: (1) likelihood of surgically correctable lesions, (2) expected benefits of revascularization, and (3) expected risks and potential harms of revascularization. Counseling should be based on patients' individual characteristics, particularly on an assessment of patients' risk factors for coronary artery disease. Patients can be classified into three major subgroups: (1) patients who have neither angina pectoris nor a history of MI, (2) patients who have no significant angina but have a history of MI, and (3) patients who have significant angina.

### Patients Without Angina or History of MI

It is unclear whether patients without a history of MI or significant angina should be routinely evaluated for ischemia. Patients should be counseled concerning the expected benefits and risks of evaluation for ischemia, including the fact that there is no evidence from controlled trials to show that revascularization benefits heart failure patients in the absence of angina.

The likelihood of coronary disease in heart failure patients without angina or history of MI varies with patient risk factors (e.g., age, sex, smoking history, hyperlipidemia, hypertension, family history of premature coronary artery disease, and diabetes).

### Patients Without Angina but With History of MI

Patients without significant angina but with a history of MI should be advised to undergo a physiologic test for ischemia, followed by coronary artery angiography if ischemic regions are detected.

Available evidence suggests that about 40-45 percent of patients who suffer an MI have clinically important myocardial ischemia in areas supplied by other coronary arteries. There are no data, however, to show that revascularization of these areas is beneficial (in terms of increased life expectancy or enhanced quality of life) if angina or anginal equivalent is not present. Nevertheless, patients with large areas of ischemia may possibly benefit from revascularization.

### Physiologic Testing

Although there are a number of acceptable physiologic tests for ischemia, the most widely available and accepted procedure for determining the presence of ischemic myocardium is myocardial perfusion scintigraphy, such as thallium scanning, with poststress, redistribution, and rest reinjection imaging.

### Patients With Significant Concomitant Angina

Heart failure patients without contraindications to revascularization who have exercise-limiting angina, angina that occurs frequently at rest, or recurrent episodes of acute pulmonary edema should be advised to undergo coronary artery angiography as the initial test for operable coronary lesions.

The potential benefit of revascularization is clearest and probably highest in individuals with severe or limiting angina or angina equivalent (e.g., recurrent acute episodes of pulmonary edema despite appropriate medical management).

Some patients may need physiologic testing for ischemia to interpret the significance of the findings from coronary artery angiography.

### Patient Counseling and Decision

Based on the results of physiologic testing and/or coronary artery angiography, the physician should give the patient a refined estimate of the risks and benefits of revascularization. The patient can then decide whether he or she desires revascularization.

### Continue Medical Management

The medical therapy started at Initial Pharmacological Management should be continued if (1) a patient is not a candidate for revascularization, (2) studies show insufficient evidence of reversible ischemia, or (3) surgery has been performed but the patient has residual left-ventricular dysfunction.

### Revascularization

Coronary artery bypass grafting (CABG) is the only revascularization procedure that has been shown to prolong life in patients with heart failure and angina. The effect of percutaneous transluminal coronary angioplasty (PTCA) on survival has not been studied. The choice between CABG and PTCA will depend on numerous considerations, including multiple technical factors (e.g., coronary anatomy), relative risk of the two procedures in individual patients, and patient preferences.

### Approaches to Patient Monitoring and Followup Evaluation

Careful history and physical examination should be the main guide to determining outcomes and directing therapy. A thorough history should include questions regarding physical functioning, mental health, sleep disturbance, sexual function, cognitive function, and ability to perform usual work and social activities.

The panel recommends against the routine use of invasive or noninvasive tests, such as echocardiography or maximal exercise testing for monitoring patients with heart failure.

Patients should be encouraged to keep records of their daily weights and to bring those records with them when visiting their practitioners. Patients should be instructed to call their practitioners if they have experienced an unexplained weight gain greater than 3-5 pounds since their last clinical evaluation.

### Additional Pharmacological Management

If patients remain symptomatic on a combination of a diuretic, an ACE inhibitor, and digoxin, a consultation should be obtained with a practitioner who has expertise in the management of heart failure, if this has not been done previously.

Patients with persistent volume overload despite initial medical management may require more aggressive administration of the current diuretic (e.g., intravenous administration), more potent diuretics, or a combination of diuretics.

Patients with persistent dyspnea after optimal doses of diuretics, ACE inhibitors, and digoxin should be given a trial of hydralazine and/or nitrates.

Beta-adrenergic blockers may improve functional status and natural history in patients with heart failure, but this form of treatment should be considered investigational at this time.

### Consideration of Heart Transplantation

Consideration should be given to cardiac transplantation in patients with severe limitation or repeated hospitalizations because of heart failure despite aggressive medical therapy in whom revascularization is not likely to convey benefit.

Patients with severe symptoms should be referred to a cardiologist to ensure that medical therapy is optimized before referral for possible transplantation. Practitioners should refer to existing documents concerning heart transplantation for further information concerning patient selection criteria.