# Acknowledgments

Heart Failure: Evaluation and Care of Patients With Left-Ventricular Systolic Dysfunctionresulted from the dedicated efforts of many individuals. The Heart Failure Panel acknowledges the many contributors whose expertise and assistance made the guideline feasible. Individuals listed in the Contributors section assisted in the intense effort required to develop this guideline on the complex issue of the appropriate evaluation and care of patients with heart failure. Efforts of peer and pilot reviewers are especially appreciated.