# Project Staff, RAND

- David C. Hadorn, MD
- Project Director
- David W. Baker, MD, MPH
- Associate Project Director Literature Review Manager
- James Hodges, PhD
- Project Statistician
- Carole Oken, MA
- Administrative Coordinator
- Caren Kamberg, MSPH
- Editor
- Roberta Shanman, MLS
- Research Librarian
- Project Secretaries
- Lauren Camhi
- Karla Danford
- Yasmin Facey
- Amy Tauber