# Panel Members

- Marvin A. Konstam, MD Co-chair
- Professor of Medicine
- Tufts University
- Director, Heart Failure and Cardiac Transplant Center
- New England Medical Center Hospitals
- Boston, Massachusetts
- Specialty: Cardiology
- Kathleen Dracup, DNSc, RN Co-chair
- Professor School of Nursing
- University of California
- Los Angeles, California
- Specialty: Cardiovascular Nursing
- Michael B. Bottorff, PharmD
- Associate Professor and Chairman Division of Clinical and Hospital Pharmacy
- University of Cincinnati College of Pharmacy
- Cincinnati, Ohio
- Specialty: Clinical Pharmacy
- Neil H. Brooks, MD
- The American Academy of Family Physicians
- Rockville, Connecticut
- Specialty: Family Practice
- Robert A. Dacey
- Former President
- The Mended Hearts, Inc.
- Boulder, Colorado
- Specialty: Consumer Representative
- Sandra B. Dunbar, DSN, RN
- Associate Professor
- Emory University Nell Hodgson Woodruff School of Nursing
- Atlanta, Georgia
- Specialty: Critical Care Nursing
- Anne B. Jackson, MA, RN
- American Association of Retired Persons National Legislative Council
- Sarasota, Florida
- Specialty: Nursing, Consumer Representative
- Mariell Jessup, MD
- Associate Professor of Medicine
- University of Pennsylvania School of Medicine
- Director, Heart Failure Unit, Risk Reduction Center
- Presbyterian Medical Center
- Philadelphia, Pennsylvania
- Specialty: Cardiology
- Jerry C. Johnson, MD
- Associate Professor of Medicine
- University of Pennsylvania
- Chief, Geriatric Medicine Division, Veterans Affairs Medical Center
- Philadelphia, Pennsylvania
- Specialty: Geriatrics and Internal Medicine
- Robert H. Jones, MD
- Mary and Deryl Hart Professor of Surgery
- Duke University Medical Center
- Durham, North Carolina
- Specialty: Cardiothoracic Surgery
- Robert J. Luchi, MD
- Chief, Geriatrics Section Director, Huffington Center on Aging
- Baylor College of Medicine
- ACOS Geriatrics and Extended Care
- Veterans Affairs Medical Center
- Houston, Texas
- Specialty: Geriatrics, General Internal Medicine
- Barry M. Massie, MD
- Professor of Medicine
- University of California, San Francisco
- Director, Hypertension Clinic Director, Coronary Care Unit
- Veterans Affairs Medical Center
- San Francisco, California
- Specialty: Cardiology
- Bertram Pitt, MD
- Professor of Internal Medicine and Associate Chairman of Academic and Industrial Programs
- Department of Internal Medicine University of Michigan Medical Center
- Ann Arbor, Michigan
- Specialty: Cardiology
- Eric A. Rose, MD
- Chief, Cardiothoracic Surgery
- Columbia Presbyterian Medical Center
- New York, New York
- Specialty: Cardiothoracic Surgery
- Lewis J. Rubin, MD
- Professor of Physiology and Professor of Medicine
- University of Maryland School of Medicine
- Baltimore, Maryland
- Specialty: Pulmonology
- Richard F. Wright, MD
- Research Director
- Pacific Heart Institute
- Assistant Clinical Professor
- University of California
- Los Angeles, California
- Specialty: Cardiology