# Foreword

Heart failure is a clinical syndrome or condition characterized by (1) signs and symptoms of intravascular and interstitial volume overload, including shortness of breath, rales, and edema, or (2) manifestations of inadequate tissue perfusion, such as fatigue or poor exercise tolerance. These signs and symptoms result when the heart is unable to generate a cardiac output sufficient to meet the body's demands. This guideline uses the term "heart failure" in preference to the commonly used "congestive heart failure" because many patients with heart failure do not manifest pulmonary or systemic congestion.

Heart failure is a major public health problem. The National Heart, Lung, and Blood Institute has estimated that more than 2 million Americans have heart failure and that about 400,000 new cases of heart failure are diagnosed each year. Total treatment costs for heart failure-including physician visits, drugs, and nursing home stays-were more than $10 billion in 1990.

The Agency for Health Care Policy and Research (AHCPR) sponsored development of this Clinical Practice Guideline. It provides recommendations for the evaluation and care of patients with heart failure due to reduced left-ventricular systolic function, which is the most common type of heart failure. It touches only briefly on the management of patients with heart failure occurring despite normal ventricular systolic performance, and it does not address the management of patients with surgically correctable valvular disease. Except as noted, the recommendations in this guideline apply to both inpatient and outpatient settings. Specialized techniques used only in the hospital setting-such as right-heart catheterization and cardiac assist devices-are not discussed.

The recommendations in this guideline are based on evidence obtained through extensive literature reviews. Where such evidence was lacking, consensus opinion of a panel of selected experts and consumers was used to formulate recommendations. Details of the literature reviews and related analyses are reported in a companion Guideline Technical Report, available from the National Technical Information Service. The panel obtained the advice and guidance of about 50 experts and clinicians concerning both the content of the guideline recommendations and the usefulness of the guideline in clinical practice.

This is the first edition of the Clinical Practice Guideline on heart failure. It will be updated to reflect advances in science and technology. Comments on the guideline are welcomed by AHCPR. Please address comments to the Director, Office of the Forum for Quality and Effectiveness in Health Care, AHCPR, Willco Building, 6000 Executive Boulevard, Suite 310, Rockville, MD 20852.

- Heart Failure Guideline Panel