# Assessment of Outcomes and Patient Followup

Careful history and physical examination should be the main guide to determining outcomes and directing therapy. A thorough history should include questions regarding physical functioning, mental health, sleep disturbance, sexual function, cognitive function, and ability to perform usual work and social activities. (Strength of Evidence = B.)

The panel recommends against the routine use of invasive or noninvasive tests, such as echocardiography or maximal exercise testing, for monitoring patients with heart failure. (Strength of Evidence = B.)

Patients should be encouraged to keep a record of their daily weights and to bring the record with them when visiting their practitioner. Patients should be instructed to call if they experience an unexplained weight gain greater than 3-5 pounds since their last clinical evaluation. (Strength of Evidence = C.)

The criteria for assessing the response to therapy are similar to those by which heart failure is diagnosed-namely, the symptoms and physical findings discussed previously. On followup visits, patients should be asked about the presence of orthopnea, paroxysmal nocturnal dyspnea, edema, and dyspnea on exertion. As discussed previously, the presence and degree of orthopnea in particular can serve as a useful monitoring criterion.

Providers should determine and document the most strenuous activity that patients can perform without significant symptoms (i.e., their maximal asymptomatic activity), the type of activity that regularly produces symptoms, and the maximal activity that patients can perform (maximal tolerated activity). These activities can be defined in terms of walking (with attention to distance, pace, and grade), stair climbing, or activities of daily living (e.g., bathing, dressing). Having defined these activities for individual patients, providers can then monitor patients' progress from visit to visit using a series of open-ended questions regarding these specific activities.

It is important to remember that patients may experience worsening symptoms before there is evidence of a deteriorating condition by physical examination. Family members or other caregivers can often contribute important additional information about patients' status and compliance when asked similar questions. Family members or other caregivers should be interviewed separately from the patients when feasible to obtain the most candid information possible and to specifically address family members' or other caregivers' concerns.

In addition to questions about symptoms and activities, providers should ask about other aspects of patients' health-related quality of life (HRQOL), including sleep; sexual function; mental health (or outlook on life); and the patient's ability to perform his or her usual social, recreational, and work activities. Cognitive function-such as alertness, memory, and concentration-should also be explored.

Several HRQOL questionnaires have been developed specifically for patients with heart failure. [223-226] Formal use of these specific questionnaires is not essential, but questions adapted from these instruments could improve and standardize history taking. The reliability of patient histories is improved when patients are asked several questions about each of the major dimensions of HRQOL (i.e., symptoms, physical functioning, and mental health), rather than single questions in each area. Moreover, the rather large number of important topics listed above suggests that use of a formal questionnaire could facilitate history taking in patients with heart failure.

The information obtained from assessing HRQOL should be used to modify treatment and to guide additional patient and family teaching and counseling. Practitioners can enhance the patient's and family's ability to adapt to heart failure and its treatments by suggesting alterations in sleep, rest, or activity patterns, counseling about sexual difficulties, teaching new coping behaviors, and intervening when depression or other emotional disturbances develop.

Careful physical examination for neck vein distention, a third heart sound, rales, hepatojugular reflux, and edema is also important. The low interrater reliability of physical findings such as rales and a third heart sound [33, 34] emphasizes the need for careful examination. However, the poor predictive value of physical findings reported in the literature should be interpreted cautiously because these studies evaluated patients at a single point in time. Although the presence or absence of a third heart sound does not make or exclude the diagnosis of heart failure, if a patient with heart failure develops a new third heart sound or rales, it is likely that this patient's heart failure has worsened. Thus, physical examination may be more helpful in following patients with heart failure than in making a diagnosis.

The panel recommends against the routine use of other tests (e.g., echocardiography, maximum exercise testing) for monitoring the response of heart failure patients to treatment. Although baseline EF [171, 227-229] and maximum oxygen consumption [230] correlate with prognosis, changes in these parameters do not necessarily indicate that the prognosis has changed. Analysis of the two VHeFT trials found that a change in EF of more than 5 percent predicted subsequent survival even after adjustment for the baseline EF. [231] However, Franciosa et al. reported that minoxidil increased mean EF from 30 to 43 percent, but exercise tolerance was not improved and total clinical events (death, worsening heart failure, increased need for diuretics, angina, and arrhythmias) were increased in the group treated with minoxidil. [232] Milrinone also increases EF, [233-234] but it has not been shown to improve survival. [235]

Even if the VHeFT results prove to be valid for groups of patients, there is too much spontaneous variability in EF for serial measurement to be useful for individuals. Narahara et al. reported a variation in left-ventricular EF of 5.6±5.5 percent over a 12-week period. [236] A change in EF of more than 13 percent would be required to exclude spontaneous variations as the cause of the change. Wackers et al. reported smaller spontaneous variability (2.3±2.5 percent), but there were only 5 days between the two measurements. [237] Finally, detecting patients with a declining EF is of limited value because there is no evidence that intensifying treatment will alter their prognosis.

In view of the preceding, repeated assessment of EF or exercise tolerance is generally not indicated. However, repeat testing may be useful in patients with a new murmur, new MI, sudden deterioration despite compliance with medications and diet, or progressive symptoms that suggest the need to refer the patient for consideration of heart transplantation.