# The Role of Revascularization

Note: Figure 4 shows the content and organization of this chapter.

Figure 4. Evaluation and Treatment of Coronary Artery Disease in Patients With Heart Failure

## Heart Failure and Coronary Artery Disease

Coronary artery disease was the second most common identifiable risk factor for heart failure (after hypertension) in the Framingham study [126] but may now well be the most common etiology. The risk of developing heart failure is increased 2-3 times in patients with angina and 4-6 times for patients with a previous MI. [190] In the SOLVD trial, 38 percent of patients had current angina, and 66 percent had suffered a previous MI. [18] Most patients with angina and some patients with a previous MI have areas of myocardial ischemia that contribute to the degree of left-ventricular systolic dysfunction. This suggests that there may be a large number of patients with heart failure and potentially reversible ischemia.

Unfortunately, there are few published data on the prevalence of clinically significant ischemia in patients with heart failure. To provide guidance to clinicians, the panel defined three subgroups of heart failure patients who are likely to have very different probabilities of significant ischemia: patients with (1) angina, (2) a history of MI but no current angina, and (3) neither angina nor a past history of MI. Although patients with heart failure and normal epicardial coronary arteries can have exertional chest pain, [127, 191, 192] the majority of patients with this combination of symptoms will have some degree of myocardial ischemia due to epicardial coronary artery disease. Patients who have suffered previous MI's may have areas of viable myocardium in the region of the infarction or ischemic regions supplied by other coronary arteries.

Kotler and Diamond have summarized studies of the detection of multivessel disease following MI. [193] In these reports, 31-56 percent (weighted average: 44 percent) of patients who suffered an MI had significant ischemia in the distribution of another coronary artery. It is unclear how many of these patients had significant angina or heart failure. This finding suggests that a substantial number of patients with heart failure and a previous MI may have other significant areas of ischemia. Whether detection and correction of this "silent" ischemia would improve prognosis is not known. This issue is discussed subsequently in more detail.

Even less is known about the prevalence of significant ischemia in patients with heart failure and no angina or prior MI. The likelihood of ischemia in a given patient is highly dependent on the presence of other risk factors for heart failure (e.g., alcoholism, severe hypertension) and risk factors for coronary artery disease (e.g., age, sex, diabetes mellitus, smoking, family history, hypertension, hypercholesterolemia). Patients with multiple risk factors for coronary artery disease and no other obvious etiology for heart failure have a much higher likelihood of having reversible ischemia as a causative or contributing factor to their heart failure. Thus, it is probably worthwhile to pursue an evaluation for ischemia in such patients. Patients with another obvious etiology for heart failure and a low risk for coronary disease are much less likely to benefit from testing.

## Benefits of CABG

For patients with ischemic cardiomyopathy, the goal of myocardial revascularization is to prevent further ischemic injury to remaining functional myocardium or to restore function to so-called hibernating myocardium (i.e., nonfunctional myocardial wall segments that are underperfused but still viable). Although it has not been proven that achievement of these goals increases survival in patients with compromised left-ventricular function, some survival benefit seems likely. Conversely, patients without remaining ischemic functional or hibernating myocardium are unlikely to benefit from revascularization.

No RCT's have evaluated the outcomes of revascularization in heart failure patients. The three RCT's of CABG versus medical management all excluded patients with heart failure or severe left-ventricular dysfunction (EF <35 percent), [194-196] so these studies cannot answer the question of whether CABG is beneficial for patients with heart failure. However, most cohort studies that have evaluated the effect of CABG on survival in patients with both heart failure or severe left-ventricular dysfunction and severe or limiting angina ( Table 8) have shown positive results. [9, 196-204] For example, Bounous et al. [9] found that adjusted 3-year mortality was reduced from 32 percent for the medical cohort to 14 percent for the surgical cohort. This differential benefit may persist for many years. [205] However, interpretation and generalization of these findings are limited because operative mortality was not reported and most patients who underwent CABG were without heart failure symptoms at the time of surgery.

Table 8. Cohort Studies of CABG Versus Medical Management for Patients With Heart Failure or Reduced EF and Coronary Artery Disease

Author, Date | Study Years | Inclusion Criteria | Group | | Average Age (years)[a] | Percentage With Clinical Heart Failure[a] | Percentage With Limiting Angina[a] | Mean Ejection Fraction[a] | Operative Mortality (percent) | Followup (years) | Total Mortality (percent) | Absolute Mortality Difference[b] (percent)
Yatteau et al., 1974[202] | 1968-72 | EF < 25% | Medical | 42 | 55 | (50) | (76) | (19%) | NA | 1.0 | 31 | -19
Yatteau et al., 1974[202] | 1968-72 | EF < 25% | Surgical | 24 | 51 | | | | 33 | | 50
Manley et al., 1976[198] | 1968-71 | Depressed left-ventricular function | Medical | 155 | 55 | 60 | 100 | 29% | NA | 6.0 | 68 | 25
Manley et al., 1976[198] | 1968-71 | Depressed left-ventricular function | Surgical | 246 | 54 | 56 | 100 | 24% | 14 | | 43
Faulkner et al., 1977[197] | 1969-75 | EF < 30% | Medical | 70 | 56 | 66 | 74 | 20% | NA | 2.0 | 53 | 30
Faulkner et al., 1977[197] | 1969-75 | EF < 30% | Surgical | 46 | 56 | 43 | 98 | 21% | 4 | | 23
Vliestra et al.,1977[200] | 1966-72 | EF < 25% | Medical | 21 | (52) | NR | 100 | NR | NA | 2.0 | 67 | 7
Vliestra et al.,1977[200] | 1966-72 | EF < 25% | Surgical | 10 | | | | NR | NR | | 60
Pigott et al., 1982[199] | 1970-77 | EF < 35% | Medical | 115 | 54 | 26 | 37 | 25% | NA | 5.0 | 66 | 29
Pigott et al., 1982[199] | 1970-77 | EF < 35% | Surgical | 77 | 54 | 21 | 65 | 27% | 1.3 | | 37
Alderman et al.,1983[196] | 1975-79 | EF >= 35% | Medical | 420 | 54 | 19 | 51 | 26% | NA | 3.0 | 33 | 10
Alderman et al.,1983[196] | 1975-79 | EF >= 35% | Surgical | 231 | 56 | 11 | 72 | 27% | 7 | | 23
Hammermeister et al.,1982[201] | 1969-74 | Clinical heart failure | Medical | 44 | (53) | 100 | (82) | NR | NA | 6.0 | Hazard ratio 0.85[c] | NA
Hammermeister et al.,1982[201] | 1969-74 | Clinical heart failure | Surgical | 83 | (54) | 100 | (96) | NR | NR | | 32[d]
Bounous et al., 1988[9] | 1976-83 | EF >= 40% | Medical | 409 | 54 | NR | NR | 29% | NA | 3.0 | 14[d] | 18
Bounous et al., 1988[9] | 1976-83 | EF >= 40% | Surgical | 301 | 55 | NR | NR | 33% | NR

[a] Numbers in parentheses indicate values for a larger group of patients in the study or for the combination of medical and surgical patients. Data on subsets of patients were not given.

[b] Medical mortality minus surgical mortality.

[c]Hazard ratio for death in patients with clinical heart failure treated with surgery compared with medical management.

[d]Adjusted for baseline prognostic factors.

Note: CABG = coronary artery bypass graft surgery, EF = ejection fraction, NA = not applicable, NR = not reported.

CABG has not been shown to improve survival in patients with heart failure who do not have angina. Although individual case reports suggest that some heart failure patients with large areas of reversible ischemia and no history of angina are improved with CABG, [206, 207] several case series and cohort studies show no evidence that patients without angina benefit from surgery. [196, 202, 208, 209] Alderman et al. [196] analyzed the Coronary Artery Surgery Study registry from 1975 to 1979 and found that patients with dyspnea on exertion or fatigue as their predominant complaint had the same 3-year mortality and symptom-free survival with CABG as with medical management (both 45.2 percent). The perioperative mortality rate was 7 percent. It is not clear whether more modern surgical techniques produce fewer perioperative deaths and better outcomes from surgery than reported in these studies.

In patients without angina, revascularization is most likely to be beneficial in the subset of patients with demonstrable myocardial ischemia or large areas of residual viable but jeopardized or hibernating myocardium. It is reasonable to assume that CABG in these patients would result in somewhat less reduction in mortality than that observed for patients with angina, although patients with large areas of ischemia might obtain a degree of improvement comparable to that seen in patients with angina. Also, patients whose heart failure symptoms are felt to represent ischemia (i.e., angina equivalent), such as those with episodic, severe heart failure or exertional dyspnea out of proportion to the degree of resting left-ventricular dysfunction, may benefit from revascularization as much as patients with angina. Patients who have only small amounts of ischemia would probably receive little or no benefit. However, there are no controlled studies to support any particular viewpoint on this subject.

## Risks of CABG

As recently as 1982, EF was considered the most important predictor of perioperative mortality for CABG. In 1986, improved perioperative and surgical techniques had reduced EF to the fourth most important predictor, behind repeat CABG, emergent CABG, and age. [210] However, patients with depressed left-ventricular function are still at increased mortality risk. [210-212] It is difficult to predict the actual perioperative mortality risk in patients with heart failure. Compared with patients with EF's of 40 percent or greater, patients whose EF's were below 20 percent or between 20 and 39 percent had 3.4 and 1.5 times the chance of dying in the perioperative period, respectively [211] Christakis et al. reported a perioperative mortality rate of 11.7 percent in a series of 264 patients with EF's below 20 percent who underwent CABG at the University of Toronto between 1982 and 1986. [210]

Mortality rates increase substantially when the EF is below 20 percent or the heart failure is severe (NYHA Class IV). [210-212] Important additional determinants of mortality risk with CABG include age (risk increases approximately 0.5 percent per year above age 60); sex (higher in women, although part of this difference is explained by a higher mortality rate in small individuals); comorbid conditions (e.g., diabetes, significant renal dysfunction, significant COPD, or clinical cerebrovascular disease); prior cardiothoracic surgery (substantially increases risk); need for emergent CABG (e.g., failed PTCA or acute ischemic syndrome) or concomitant valve surgery. [209, 211, 212]

These studies indicate that for patients with clinical heart failure due to left-ventricular systolic dysfunction, perioperative mortality rates in excellent centers will range from about 5 percent in patients under age 60 with mild heart failure without any comorbid conditions to more than 30 percent in patients over age 70 with severe heart failure and several comorbid conditions. In addition to mortality risk, the risk of surgical morbidity and complications must also be considered. In the New York State Cardiac Surgery Reporting System, the risk of perioperative MI was 1.5 percent, the risk of stroke was 1.6 percent, and the risk of all major nonfatal complications was 9.2 percent. [211] Centers and surgeons vary considerably in their experience with patients with severe left-ventricular dysfunction. Perioperative mortality rates for CABG also vary significantly. [213] Patients should be informed of the mortality and complication rates of the surgeon performing the operation and of the facility where the surgery will be done. The patient's primary provider should be aware of variations in operative outcomes and consider referral to a center with substantial experience with heart failure patients and demonstrated good outcomes.

## Benefits and Risks of PTCA

As with CABG, the benefits of PTCA in patients with heart failure are unclear. No studies have addressed survival after PTCA compared with CABG or standard medical management. However, several case reports and case series indicate that PTCA can relieve angina and improve ventricular function or wall motion. [214-219]

Less is known about the risks of PTCA for patients with heart failure. Serota et al. reported a series of 73 patients with EF of 40 percent or less who underwent PTCA, 45 percent of whom had a history of heart failure. [218] Five patients (7 percent) had serious procedure-related complications; of the three patients with MI's, two were fatal; and two had acute coronary closure with one patient death related to acute closure. The total in-hospital mortality was 5.5 percent. Hartzler et al. reported a "procedural mortality" of 2.7 percent for a series of 664 patients with EF's of 40 percent or less who underwent PTCA. [215] The rates of nonfatal MI and emergent CABG were 0.7 and 2.0 percent, respectively. The patient populations and reporting techniques in these series are different from those reported in studies of CABG, so a direct comparison is not possible. Thus, it is not known whether PTCA has a higher, lower, or equivalent complication rate for patients with heart failure, compared with CABG.

Because PTCA has not been shown to improve survival, CABG is usually considered the procedure of choice for patients with heart failure and angina. However, numerous considerations enter into the decision regarding recommendation of PTCA versus CABG, including multiple technical factors, underlying risk of surgery, the greater morbidity associated with CABG, and patient preferences. A discussion of these factors is beyond the scope of this guideline.

## Patient Counseling and Decisionmaking

Patients without contraindication to revascularization should be advised of the possibility of revascularization, including its potential benefits and harms. Before embarking on an evaluation for ischemia, practitioners should determine whether patients are willing to consider revascularization or have contraindications to revascularization. (Strength of Evidence = C.)

Patients with heart failure and angina should be advised to undergo coronary artery angiography if they are surgical candidates. (Strength of Evidence = C.)

There are no absolute contraindications to revascularization except if the patient refuses surgery or is unable to give informed consent. However, a number of factors may preclude intervention or raise the risk above any expected benefit:

- Unwillingness to consider surgery.
- Severe comorbid diseases, especially renal failure, pulmonary disease, or cerebrovascular disease (e.g., severe stroke).
- Very low EF (<20 percent).
- Illnesses that imply a limited life expectancy less than or equal to 1 year, including advanced cancer, severe lung or liver disease, chronic renal disease, advanced diabetes mellitus, and advanced collagen vascular disease.
- Technical factors, including previous myocardial revascularization or other cardiac procedure, inadequate vascular conduit, history of chest irradiation, and diffuse distal obstructive coronary artery atherosclerosis.

It is important to balance the expected benefits and harms associated with revascularization. Patients may consider the relatively high perioperative mortality rate more acceptable when their life expectancy is not limited by other diseases or advanced age (i.e., when there is a good chance for long-term survival if they survive surgery). However, patients with diseases that, although not terminal, might be expected to reduce life expectancy may not consider the initial risk of perioperative mortality acceptable.

Patients, family members, and caregivers should be involved in decisionmaking at all steps of the treatment and care of heart failure, but this is particularly important when revascularization is being considered. The primary practitioner should provide patients with the information necessary to begin the decisionmaking process. Later, specialists should interact directly with the patient. Patients should be advised about the relative likelihood that they have clinically significant ischemia, about the risks of angiography, and about the likely benefits and harms of revascularization if ischemia is found. Some individuals may not want to undergo evaluation if there is a low likelihood that ischemia will be found. For others, the risks of surgery will be unacceptable regardless of the possible benefits. Patients should be encouraged to ascertain the perioperative mortality rate experienced by the providers in their area (or those covered by their insurance plan).

An individual's likelihood of having ischemia and his or her chance of surviving surgery can be estimated by the history, physical examination, and EF. These factors should be discussed with the patient before any diagnostic testing for ischemia. Some patients, in consultation with their primary practitioner, may decide at this point that no studies should be done. For other patients, this decision requires a balancing between expected benefits and risks. The amount of ischemic myocardium is the best predictor of the benefit of revascularization, and testing for the presence and amount of ischemia may be necessary before a patient can reasonably decide whether the risks of revascularization are acceptable.

If a patient wishes to pursue an evaluation for ischemia, the provider must decide what test is most appropriate.

Heart failure patients without contraindications to revascularization and who have exercise-limiting angina, angina that occurs frequently at rest, or recurrent episodes of acute pulmonary edema should be advised to undergo coronary artery angiography as the initial test for operable coronary lesions. (Strength of Evidence = B.)

Some patients will need subsequent physiologic testing to determine the amount of ischemic myocardium or whether myocardium is viable, but it is not necessary to perform such tests routinely before angiography in this subgroup of patients.

Patients without significant angina but with a history of MI should be advised to undergo a physiologic test for ischemia, followed by coronary angiography if ischemic regions are detected. (Strength of Evidence = C.)

This strategy will miss a small number of patients with false negative physiologic tests. However, in view of the lack of evidence that these patients benefit from surgery, together with a consideration of the morbidity, mortality, and cost of catheterizing all patients in this group, this drawback is considered relatively minor.

It is unclear whether patients without a history of MI or significant angina should be routinely evaluated for ischemia. Patients should be counseled concerning the expected benefits and risks of evaluation for ischemia, including the fact that there is no evidence from controlled trials to show that revascularization benefits heart failure patients in the absence of angina. The decision about whether to perform physiologic tests for ischemia or coronary angiography should be based on a consideration of patients' risk factors for coronary artery disease and the likelihood of alternative etiologies (e.g., alcoholic cardiomyopathy). If the decision is made to proceed with an evaluation, noninvasive testing for ischemia (e.g., thallium scanning) should be performed as the initial test; coronary angiography should be performed only if noninvasive testing demonstrates ischemia. (Strength of Evidence = C.)

Little scientific evidence is available to guide the evaluation and care of heart failure patients who have no history of angina or MI. Some of these individuals will have silent coronary artery disease as the cause of their heart failure, although this clearly depends on the patients' risk factors for coronary artery disease and the probability that there is another etiology for the heart failure. Patients without risk factors for coronary artery disease and patients with another probable cause of heart failure (e.g., alcoholic cardiomyopathy) are unlikely to benefit from angiography or testing for ischemia.

The panel was about evenly divided between advocating no further testing and advocating a physiologic test for ischemia in patients with no angina and no history of MI. Coronary angiography was considered advisable by some panelists in the uncommon presentation of unexplained heart failure in young patients with no history of angina or prior MI, with the rationale that these patients may benefit more from early revascularization for occult coronary artery disease than from later cardiac transplantation.

Based on the results of physiologic testing and/or coronary angiography, the physician should give the patient a refined estimate of the risks and benefits of revascularization. The patient can then decide whether he or she desires revascularization. (Strength of Evidence = C.)

No data are available that address the question of how much ischemia should be present to justify the risk of revascularization for the chance of an improvement in survival. In general, patients with severely depressed EF's (<20 percent) should undergo revascularization only if large areas of ischemia are detected. Patients with less severely depressed EF's may be willing to risk surgery for more modest-sized ischemic areas. The lack of data in this area makes it difficult to justify revascularization for small ischemic areas, except when severe angina is present.

## Physiologic Testing for Ischemia

Although there are a number of acceptable physiologic tests for ischemia, the most widely available and accepted procedure for determining the presence of ischemic myocardium is myocardial perfusion scintigraphy, such as thallium scanning, with poststress, redistribution, and rest reinjection imaging. (Strength of Evidence = C.)

Several studies have assessed the reversibility of perfusion defects or improvement in wall motion or EF after revascularization, but it is unclear whether these changes predict improvement in symptoms, exercise tolerance, or survival. Definitive outcome studies comparing the alternative tests have not been performed.

Thus, the clinician must choose from a range of acceptable alternatives. These include:

- Exercise or pharmacological stress myocardial perfusion scintigraphy (e.g., thallium scanning).
- Exercise or pharmacological stress echocardiography.
- Stress radionuclide angiocardiography.
- Positron emission tomography (PET).

If thallium is used, reinjection imaging should be performed at rest if an abnormality is identified during the stress portion of the study. This strategy improves the accuracy for identifying the presence and extent of viable myocardium. [220] PET may be a more sensitive test than perfusion scintigraphy for detecting viable myocardium, [221] but whether increased sensitivity translates into better patient outcomes is yet to be determined. In addition, PET is not widely available and is more costly than most alternative tests. Clinicians must be familiar with the availability, quality, and cost of the different physiologic tests for ischemia at their institution and should use this information in deciding what test to order. Myocardial perfusion scintigraphy is most useful for screening patients without a history of angina to determine whether coronary angiography is necessary. If this test is normal, angiography can reasonably be forgone. Because scintigraphy relies on differences in the distribution of myocardial perfusion to determine ischemia, an occasional patient with very balanced ischemia may have a "normal" study. Increased uptake of the isotope in the lungs may be a clue to this type of false negative test.

## Evaluation for Heart Transplantation

Consideration should be given to cardiac transplantation in patients with severe limitation or repeated hospitalizations because of heart failure despite aggressive medical therapy in whom revascularization is unlikely to be beneficial. This guideline does not address the evaluation of patients for transplantation. (Strength of Evidence = C.)

In addition to heart transplantation, studies are under way to determine the benefits and harms of innovative treatments, including new drugs and mechanical ventricular assist devices. If appropriate, patients should be informed of the possibility of taking part in such studies.

For more information on heart transplantation, the reader is referto the American College of Cardiology/American Heart Association report on this topic. [222]