# Pharmacological Management

Note: Figure 3 shows the content and organization of this chapter.

Figure 3. Pharmacological Management of Patients With Heart Failure

## Initial Pharmacological Management

### Diuretic Therapy

Patients with heart failure and signs of significant volume overload should be started immediately on a diuretic. Patients with mild volume overload can be managed adequately on thiazide diuretics, whereas those with more severe volume overload should be started on a loop diuretic. (Strength of Evidence = C.)

Symptoms of volume overload include orthopnea, paroxysmal nocturnal dyspnea, and dyspnea on exertion; signs include pulmonary rales, a third heart sound, jugular venous distention, hepatic engorgement, ascites, peripheral edema, and pulmonary vascular congestion or pulmonary edema on chest x-ray. There are few studies of optimal diuretic therapy for heart failure. Patients with mild heart failure can usually be managed adequately on thiazide diuretics. [132, 133] Moreover, some patients prefer a thiazide diuretic over furosemide, probably because it causes less acute diuresis than furosemide. [132] If a patient has severe volume overload at the time of presentation, severe renal insufficiency (estimated creatinine clearance <30 mL/min), or persistent edema despite thiazide diuretics, a loop diuretic should be used instead of a thiazide. Treatment of mild heart failure with ACE inhibitors alone is discussed in the next section.

Diuretic dosing is summarized in Table 6. Proper dosing depends on the patient's size, age, renal function, compliance with dietary sodium restriction, and the amount of edema. Hydrochlorothiazide should generally be given in doses of 25-50 mg per day. Patients who have persistent volume overload on 50 mg of hydrochlorothiazide per day or the equivalent should be changed to a loop diuretic. Furosemide should be started at 20-40 mg once daily. Elderly patients may be started on 10 mg per day initially. In elderly patients with urinary incontinence or urgency, guidance should be provided concerning the timing of diuretic administration (especially loop diuretics) in relation to the patient's activities to minimize noncompliance and prevent patients from isolating themselves from society.

Table 6. Medications Commonly Used for Heart Failure

Drug | Initial Dose (mg) | Target Dose (mg) | Recommended Maximal Dose (mg) | Major Adverse Reactions
Thiazide Diuretics
Hydrochlorothiazide | 25 QD | As needed | 50 QD | Postural hypotension, hypokalemia, hyperglycemia, hyperuricemia, rash. Rare severe reaction includes pancreatitis, bone marrow suppression, and anaphylaxis.
Chlorthalidone | 25 QD | As needed | 50 QD | Postural hypotension, hypokalemia, hyperglycemia, hyperuricemia, rash. Rare severe reaction includes pancreatitis, bone marrow suppression, and anaphylaxis.
Loop Diuretics
Furosemide | 10-40 QD | As needed | 240 BID | Same as thiazide diuretics.
Bumetanide | 0.5- 1.0 QD | As needed | 10 QD | Same as thiazide diuretics.
Ethacrynic acid | 50 QD | As needed | 200 BID | Same as thiazide diuretics.
Thiazide-Related Diuretic
Metalazone | 2.5[a] | As needed | 10 QD | Same as thiazide diuretics.
Potassium-Sparing Diuretics
Spironolactone | 25 QD | As needed | 100 BID | Hyperkalemia, especially if administered with ACE inhibitor; rash; gynecomastia (spironolactone only).
Triamterene | 50 QD | As needed | 100 BID | Hyperkalemia, especially if administered with ACE inhibitor; rash; gynecomastia (spironolactone only).
Amiloride | 5 QD | As needed | 40 QD | Hyperkalemia, especially if administered with ACE inhibitor; rash; gynecomastia (spironolactone only).
ACE Inhibitors
Enalapril | 2.5 BID | 10 BID | 20 BID | Hypotension, hyperkalemia, renal insufficiency, cough, skin rash, angioedema, neutropenia.
Captopril | 6.25-12.5 TID | 50 TID | 100 TID | Hypotension, hyperkalemia, renal insufficiency, cough, skin rash, angioedema, neutropenia.
Lisinopril | 5 QD | 20 QD | 40 QD | Hypotension, hyperkalemia, renal insufficiency, cough, skin rash, angioedema, neutropenia.
Quinapril | 5 BID | 20 BID | 20 BID | Hypotension, hyperkalemia, renal insufficiency, cough, skin rash, angioedema, neutropenia.
Digoxin | See pages 58-60 | See pages 58-60 | See pages 58-60 | Cardiotoxicity, confusion, nausea, anorexia, visual disturbances.
Hydralazine | 10-25 TID | 75 TID | 100 TID | Headache, nausea, dizziness, tachycardia, lupus-like syndrome.
Isosorbide Dinitrate | 10 TID | 40 TID | 80 TID | Headache, hypotension, flushing.

[a] Given as a single test dose initially.

Note: ACE = angiotensin-converting enzyme,BID = twice a day, QD = once a day,TID = three times a day.

Patients with pulmonary edema or with marked volume overload (e.g., anasarca) should be given intravenous furosemide initially. Diuretics should then be titrated to achieve resolution or improvement of signs and symptoms of volume overload. There is no standard target dose. Occasionally, a patient with mild heart failure may require a diuretic on alternating days or as needed.

It is generally better to give hydrochlorothiazide or furosemide as a single daily dose in the outpatient setting. If the initial oral dose is inadequate, more diuresis will usually be obtained by doubling the dose rather than by giving the same dose twice daily. At high doses, furosemide can be given twice daily, but it should usually not be given more frequently. Inpatients with severe volume overload may require more frequent intravenous doses to obtain the desired brisk diuresis. Doses of furosemide as high as 240 mg twice per day may be required in the most refractory patients, but doses over about 160 mg per day usually require additional efforts to improve diuresis (discussed subsequently). It is very important to avoid excessive diuresis before starting ACE inhibitors. Volume depletion may lead to hypotension or renal insufficiency when ACE inhibitors are started. The ACE inhibitor may facilitate diuresis in some patients. In general, the dose of diuretic may be increased in parallel with the ACE inhibitor, but it is important to avoid excessive diuresis that could prevent titrating the ACE inhibitor to full therapeutic levels.

Potassium depletion commonly occurs when patients are treated chronically with diuretics. However, ACE inhibitors decrease renal potassium losses and raise serum potassium levels, so many patients with heart failure who are treated with both agents may not develop potassium depletion. All patients should have their serum potassium levels checked frequently (e.g., every 3 days until stable) during initiation, titration, or modification of diuretic or ACE inhibitor therapy and every few months thereafter. Note, however, that serum potassium can be an unreliable indicator of total body potassium stores; patients with normal serum potassium levels can have low total body potassium stores. [133, 134] Thus, patients who have a serum potassium less than 4.0 mEq/L should be given a potassium-sparing agent or oral potassium supplementation.

Potassium-sparing diuretics may be more effective than oral potassium supplements at maintaining total body potassium stores. [134] When an ACE inhibitor is used together with a potassium-sparing agent or potassium supplements, the serum potassium level must be followed closely (e.g., every 3 days until stable).

Diuretics can also cause magnesium depletion, which often accompanies potassium depletion. If high doses of diuretics are used, magnesium levels should be followed and oral supplementation given when necessary. Hypocalcemia may be a useful clue to possible significant hypomagnesemia.

### ACE Inhibitors

Patients with heart failure due to left-ventricular systolic dysfunction should be given a trial of ACE inhibitors unless specific contraindications exist: (1) history of intolerance or adverse reactions to these agents, (2) serum potassium greater than 5.5 mEq/L that cannot be reduced, or (3) symptomatic hypotension (see below). Patients with systolic blood pressures less than 90 mmHg have a higher risk of complications and should be managed by a physician experienced in utilizing ACE inhibitors in such patients. (Strength of Evidence = A.) Caution and close monitoring are also required for patients who have a serum creatinine greater than 3.0 mg/dL or an estimated creatinine clearance of less than 30 mL/min; half the usual dose should be used in this setting. (Strength of Evidence = B.)

Although there are no studies on patterns of ACE inhibitor usage in medical practice, the panel concurs with Cody's conclusion that vasodilators are underused in heart failure because of clinicians' concerns regarding excessive blood pressure reduction. [135]

ACE inhibitors may be considered as sole therapy in the subset of heart failure patients who present with fatigue or mild dyspnea on exertion and who do not have any other signs or symptoms of volume overload. Diuretics should be added if these symptoms persist. (Strength of Evidence = C.)

Most patients with heart failure have some degree of volume overload and therefore require a diuretic. However, some patients have no evidence of volume overload and present with fatigue or mild dyspnea on exertion. This population seems to fall in between the group with asymptomatic left-ventricular dysfunction (many of whom actually have poor exercise tolerance on careful questioning or exercise testing) and those patients with clinically evident heart failure. There are no data to guide appropriate care of these patients. Because ACE inhibitors should be used in all patients with left-ventricular dysfunction, regardless of symptoms, it is reasonable to start an ACE inhibitor in patients with very mild symptoms and determine whether the symptoms resolve. If symptoms do not totally resolve after the target dose of ACE inhibitor is reached, diuretics should be added.

#### >Benefits of ACE Inhibitors

The ACE inhibitor enalapril has been shown to reduce mortality in patients with moderate [18] and severe [10] heart failure; moreover, enalapril has been shown to reduce mortality more than the combination of isosorbide dinitrate and hydralazine. [19] In the CONSENSUS trial, which studied only patients with NYHA Class IV heart failure, 1-year mortality was reduced from 52 percent with placebo to 36 percent with enalapril. [10] The degree of benefit is more modest in the general heart failure population. The SOLVD treatment trial found that enalapril reduced overall 4-year mortality from 40 percent to 35 percent. [18] The survival curves indicate that median survival in patients receiving enalapril was increased by approximately 6 months. The effect of captopril on mortality in patients with clinically evident heart failure has not been studied.

Enalapril and captopril enhance functional status in patients with heart failure, with 40-80 percent of patients showing an improvement in NYHA class. [10, 18, 136-144] Although some patients may improve more than one functional class, the average improvement is 0.5-1 functional class. Beneficial effects on physical functioning have also been reported with other ACE inhibitors. [145-148] The SOLVD treatment trial also found that enalapril decreased the number of patients hospitalized over the study period from 74 to 69 percent and the number of patients hospitalized for cardiovascular reasons from 63 to 57 percent. [18] The total number of hospitalizations was also decreased by 15 percent. The beneficial effects of ACE inhibitors in the prevention of heart failure in patients with reduced left-ventricular performance have been discussed earlier in this document.

#### Side Effects of ACE Inhibitors and Contraindications

Side effects of ACE inhibitors, particularly decreases in blood pressure and increases in serum creatinine and potassium, have been emphasized in many studies. [149-159] These concerns may have made some physicians reluctant to use ACE inhibitors. However, the average changes in blood pressure and serum chemistries in the SOLVD trial were actually quite small, with systolic blood pressure decreasing an average of 5 mmHg, diastolic blood pressure decreasing 4 mmHg, creatinine increasing 0.1 mg/dL, and potassium increasing 0.2 mEq/L. [18] Only 2.2 percent of those eligible had symptomatic hypotension when enalapril was initiated. Even in the CONSENSUS trial, which enrolled only patients with NYHA Class IV heart failure, only 5.5 percent of those treated with enalapril were withdrawn because of symptomatic hypotension, and there was only a 1.5-percent increase in withdrawals due to renal insufficiency compared with patients receiving placebo. [10]

Thus, relatively low blood pressure, moderate renal insufficiency, and mild hyperkalemia are not contraindications to ACE inhibitors. If serum creatinine is 3.0 mg/dL or greater, ACE inhibitors should be used with caution and titrated upward slowly, as tolerated, to a maximum of half the usual maintenance dose. The risks and benefits in these latter patients are not known because they were excluded from major trials. Patients with lesser degrees of renal insufficiency also require close followup and reduction in doses if the glomerular filtration rate is less than 30 mL/min. A serum potassium of 5.5 mEq/L or greater is considered by most panelists to be a contraindication to ACE inhibitor therapy unless the serum potassium can be reduced.

Potassium-sparing diuretics (e.g., spironolactone, amiloride, triamterene) should be stopped in all patients who are being started on ACE inhibitors, regardless of the serum potassium. These agents may be restarted if the patient remains hypokalemic on full therapeutic doses of ACE inhibitors. Potassium supplements should usually also be withheld unless the patient has a low serum potassium (<4.0 mEq/L). If potassium supplements are continued, serum potassium levels must be followed closely (i.e., every few days until stable).

Patients with low blood pressure must also be carefully monitored, but therapy should be continued. The panel agreed with Cody, who has argued that, in the absence of orthostatic hypotension, a systolic blood pressure of 90 mmHg is perfectly acceptable. [135] Some patients with heart failure will feel best with a blood pressure below 90 mmHg. If a physician is uncomfortable starting therapy in the setting of a low blood pressure, he or she should refer the patient to someone with expertise in treating heart failure rather than abandon attempts to use ACE inhibitors or other vasodilators.

Cough is common in patients taking ACE inhibitors, but it is also common in patients with heart failure. In the SOLVD treatment trial, 37 percent of patients receiving enalapril reported cough, compared with 31 percent of those receiving placebo. [18] Cohn et al. reported similar figures, but only 1 percent of patients receiving enalapril and 1 percent of those receiving isosorbide dinitrate and hydralazine stopped the study medication because of cough. [19] Thus, patients who report cough while taking ACE inhibitors should be evaluated to see whether this results from pulmonary congestion before considering discontinuing ACE inhibitors. For most patients, the cough is a nuisance that they are willing to tolerate in exchange for the benefits of the medication. Dizziness and angioedema also occur, but these symptoms are usually mild and do not require discontinuation of the drug. Angioedema of the oropharyngeal region is an absolute contraindication to further use of an ACE inhibitor.

#### Initiating Therapy With ACE Inhibitors

In the opinion of the Heart Failure Guideline Panel, all ACE inhibitors are likely to be effective in treating heart failure; no particular agent is recommended over another. ACE inhibitors other than enalapril and captopril (e.g., lisinopril, quinapril) are available and have been shown to improve exercise tolerance. [145-148, 160] However, there are no data available on whether these other agents reduce mortality or what dose might be required to do so. Note that enalapril is the only ACE inhibitor shown to affect mortality in patients with clinically evident heart failure.

After diuretic therapy is initiated in patients with clinical volume overload and left-ventricular systolic dysfunction is confirmed as the cause of the patient's symptoms, an ACE inhibitor should be added. Patients should be assessed closely for volume depletion before therapy is initiated (orthostatic hypotension, prerenal azotemia, metabolic alkalosis), and if volume depletion is evident, diuretics should be withheld for a brief period (24-48 hours) until volume depletion resolves.

Patients who are at high risk for first-dose hypotension (severe left-ventricular systolic dysfunction, initial systolic blood pressure <100 mmHg, or serum sodium <135 mEq/L) should be given a small dose of a short-acting agent (e.g., captopril 6.25 mg) and monitored closely for 2 hours. [153] Patients over the age of 75 may also be at increased risk for hypotension and may be started on once-daily dosing initially. [156] If the test dose is tolerated, or if a test dose is unnecessary, captopril 12.5 mg TID or enalapril 2.5 mg BID can be started. Patients with hypertension can be started on captopril 25 mg TID or enalapril 5 mg BID.

Patients should be seen within 1 week of initiation of ACE inhibitor to monitor blood pressure, renal function, and serum potassium. It is appropriate to contact the patient by telephone 48 hours after an ACE inhibitor is initiated to ask about symptoms of hypotension, such as dizziness or weakness. Treatment should be modified if the patient develops (1) an increase in serum creatinine of 0.5 mg/dL or more, (2) a serum potassium of 5.5 mEq/L or higher, or (3) symptomatic hypotension. Patients who develop renal insufficiency or hypotension should have their volume status reassessed. In patients who become hypovolemic as a result of diuresis, the diuretic dose should be reduced and the ACE inhibitor tried again. Patients failing a second trial should be placed on hydralazine and isosorbide dinitrate (HYD/ISDN), as described subsequently, instead of an ACE inhibitor. If hyperkalemia develops, ACE inhibitors should not be retried, and therapy should be changed to HYD/ISDN.

Doses of ACE inhibitors should be titrated upward over 2-3 weeks with the goal of reaching the doses used in large-scale clinical trials: captopril 50 mg TID or enalapril 10 mg BID. Volume status should be reassessed if hypotension or a rise in the serum creatinine of 0.5 mg/dL occurs as the dose is increased. If there is evidence of volume depletion, the dose of the ACE inhibitor should be reduced to the highest dose that was previously tolerated and the diuretic dose reduced. The dose of the ACE inhibitor should then be increased again. If higher doses are not tolerated despite euvolemia, then the lower dose should be continued or a trial of HYD/ISDN instituted.

In patients with creatinine clearances of 30 mL/min or less, ACE inhibitors should be used with caution and titrated upward slowly, as tolerated, to a maximum of half the usual maintenance dose. With judicious dosing and close followup, almost all patients can tolerate these agents. The full effect of ACE inhibitors on functional status may not be seen for several months. Patients who tolerate the preceding doses but who remain symptomatic may benefit from higher doses (e.g., enalapril 20 mg BID or captopril 100 mg TID). Maximal doses of these agents and the risks and benefits of higher doses have not been defined.

### Digoxin

Digoxin can prevent clinical deterioration in patients with heart failure due to left-ventricular systolic dysfunction and improve patients' symptoms (Strength of Evidence = A). However, its effects on mortality are not clear. Digoxin should be used routinely in patients with severe heart failure and should be added to the medical regimen of patients with mild or moderate failure who remain symptomatic after optimal management with ACE inhibitors and diuretics. (Strength of Evidence = C.)

Cardiac glycosides have been used to treat heart failure for more than 200 years. Although they are clearly the drug of choice to treat heart failure patients with atrial fibrillation and a rapid ventricular response, their use in patients with sinus rhythm has been controversial. Although a number of cardiac glycosides are available, digoxin is commonly considered the preferred agent and is the only one discussed in this guideline. The recent RADIANCE trial has provided additional evidence that digoxin improves physical function and decreases symptoms in at least some (if not most) patients with heart failure (see subsequent discussion). [161] However, whether all patients with heart failure due to left-ventricular systolic dysfunction benefit from the addition of digoxin to a regimen of ACE inhibitors and diuretics is not clear. In addition, no RCT has yet been completed with sufficient numbers of patients to determine whether digoxin affects the mortality of patients with heart failure.

A large multicenter trial, sponsored by the National Institutes of Health, is currently under way to determine the effects of digoxin on mortality rate. At present, the effects of digoxin on mortality are unknown.

Studies that have examined digoxin's effect on functional status and nonmortality outcomes have shown conflicting results. This confusing picture has resulted in part from the large number of studies with major methodologic flaws. [162] Jaeschke et al. attempted to remedy this by analyzing only the seven randomized, placebo-controlled trials of digoxin that they found in the literature. [162] Their meta-analysis found that digoxin reduced the percentage of patients with clinical deterioration severe enough to require study withdrawal from 18 percent for those who received placebo (N = 354) to 6 percent for those who received digoxin (N = 357) (risk difference, 12 percent; 95-percent confidence interval of -20 to -3 percent). In addition, the Captopril-Digoxin Multicenter Research Group found a trend toward fewer emergency department visits or hospital admissions for heart failure in patients treated with digoxin compared with those who received placebo and a diuretic (16 versus 27 percent, p = 0.08). [163] The RADIANCE trial found that when digoxin was withdrawn from patients taking digoxin, diuretics, and an ACE inhibitor, patients were six times more likely to have clinical deterioration than patients who continued to take digoxin. [161] It is unclear, however, whether digoxin withdrawal studies are relevant to the question of when digoxin should be initiated in the first place.

Digoxin also appears to improve physical functioning and decrease symptoms in some patients with heart failure. Although the Captopril-Digoxin Multicenter Research Group [163] found no difference in exercise tolerance or NYHA classification in patients treated with digoxin, DiBianco et al. [164] found a 65-second (14-percent) increase in exercise time, and when digoxin was withdrawn from patients in the RADIANCE trial, exercise tolerance, NYHA class, and quality-of-life scores deteriorated. [161]

Based on these findings, digoxin should be initiated with ACE inhibitors and diuretics in patients with severe heart failure and should be added in patients who remain symptomatic despite optimal management with ACE inhibitors and diuretics. However, because there is no evidence that digoxin decreases mortality, patients who are asymptomatic after treatment with ACE inhibitors and diuretics may not benefit from digoxin. Some panelists employ this agent routinely in all patients with left-ventricular systolic dysfunction, however.

Loading doses of digoxin are not generally needed. In the presence of normal renal function, the typical dose of 0.25 mg daily may be instituted. Patients who have reduced renal function, have baseline conduction abnormality, or are small or elderly should be started on 0.125 mg daily or lower and titrated to an adequate serum digoxin level. Steady state will be reached in approximately 1 week in patients with normal renal function, although 2-3 weeks may be needed in patients with renal impairment. When steady state is achieved, the patient should be checked for symptoms of toxicity and an ECG, serum digoxin level, serum electrolytes, BUN, and creatinine obtained. The value of obtaining regular serum digoxin levels is uncertain, but it is probably reasonable to check levels once yearly after a steady state is achieved. In addition, levels should be checked if:

- Heart failure status worsens.
- Renal function deteriorates.
- Additional medications are added that could affect the digoxin level (see below).
- Signs of toxicity develop (e.g., confusion, nausea, anorexia, visual disturbances).

In the absence of toxicity, serum digoxin levels as high as 2.5 ng/mL may be tolerated, although levels of 0.7-1.5 ng/mL are generally considered therapeutic. It is unclear whether the beneficial effects of digoxin are greater at higher serum levels.

Digoxin should be discontinued (often with consideration of reinstitution at a lower dose after 2-3 days) if any of the following are noted:

- Elevated serum digoxin level.
- Substantial reduction in renal function.
- Symptoms of toxicity (as above).
- Significant conduction abnormality (e.g., symptomatic bradycardia due to second- or third-degree atrioventricular [AV] block or high-degree AV block in atrial fibrillation).
- Increase in ventricular arrhythmias.

Before a new medication is instituted, the prescriber should determine whether the medication interacts with digoxin. The most frequent medications that raise the digoxin level are quinidine, verapamil, and amiodarone. Additional pharmacological agents that may raise serum digoxin levels include (1) antibiotics, which may decrease gut flora and prevent bacterial inactivation of digoxin, and (2) anticholinergic agents, which decrease intestinal motility. [165] Serum digoxin levels should be checked approximately 1 week after any of these agents are added to the therapeutic regimen.

### Hydralazine/Isosorbide Dinitrate

HYD/ISDN is an appropriate alternative in patients with contraindications or intolerance to ACE inhibitors. (Strength of Evidence = B.)

Patients who have contraindications to ACE inhibitors or who cannot tolerate ACE inhibitors should be given a trial of HYD/ISDN. No studies have specifically addressed the use of HYD/ISDN for patients who cannot take or tolerate ACE inhibitors. HYD/ISDN is not as beneficial as enalapril in reducing mortality during the first 2 years of treatment. [19] However, this combination has been shown to achieve an absolute reduction in mortality, compared with placebo, from 19 to 12 percent and from 47 to 36 percent, in patients with heart failure at 1 and 3 years, respectively. [17] The mortality difference between treated and untreated patients was not significant beyond 3 years, although this may have been due to a lack of statistical power of the study beyond 3 years.

The effect of HYD/ISDN on functional status is not clear, but these agents increased exercise capacity as much as enalapril. [19] Side effects are a significant problem, however; 18-33 percent of patients in these trials discontinued one or both of the medications. Headache, palpitations, and nasal congestion occur more frequently with these medications than with ACE inhibitors. On balance, the use of HYD/ISDN represents an important alternative to ACE inhibitors when patients do not tolerate the latter class of agents.

Isosorbide dinitrate should generally be initiated at a dose of 10 mg TID and increased weekly to 40 mg TID as tolerated. Hydralazine should generally be initiated at a dose of 25 mg TID, and increased weekly to 75 mg TID. Patients with low blood pressure, severe heart failure, or advanced age can be started at 10 mg TID for both agents. In the Veterans Affairs Vasodilator-Heart Failure Trial (VHeFT) II, which compared enalapril with HYD/ISDN, the average daily doses of hydralazine and isosorbide dinitrate were 200 mg and 100 mg, respectively. [19] Lower daily doses may not be effective. Clinical trials of HYD/ISDN have used QID dosing. Although there is no evidence that TID dosing is equally efficacious, concerns about nitrate tolerance and poor compliance with QID dosing regimens makes TID dosing with these agents a more reasonable approach than QID dosing. [166]

Note that although the Food and Drug Administration (FDA) has not approved HYD/ISDN for use in patients with heart failure, these agents may nonetheless be used in this context as appropriate, in accordance with the preceding discussion.

### Anticoagulation

Routine anticoagulation is not recommended. Heart failure patients with a history of systemic or pulmonary embolism, recent atrial fibrillation, or mobile left-ventricular thrombi should be anticoagulated to a prothrombin time ratio of 1.2-1.8 times each individual laboratory control time (International Normalization Ratio of 2.0-3.0). (Strength of Evidence = C.)

Some authors have suggested that anticoagulation be "considered" for patients with heart failure, even in the absence of atrial fibrillation or history of embolism. [167, 168] However, there has never been a controlled trial of anticoagulation for patients with dilated cardiomyopathy. [169] Some information is available on the risk of stroke from retrospective studies [170-173] and a prospective study of patients with heart failure. [18] The rate varied in these studies from 1.4 to 5.5 strokes per 100 patient-years. One study reported an incidence of 42 strokes per 100 patient-years. [167] Selection bias in such observational studies may result in a higher incidence of stroke than exists for typical patients with heart failure.

Data on fatal stroke are available from recent RCT's of ACE inhibitors, although the total number of strokes has not been reported. In the SOLVD trial, which included patients with NYHA Class II or III heart failure, the incidence of fatal stroke was only 0.24 per 100 patient-years. [18] The CONSENSUS trial included only patients with NYHA Class IV heart failure. [10] Half of those enrolled had atrial fibrillation, but only one-third of all patients were receiving anticoagulation at the start of the trial. Of 253 patients, 3 suffered a stroke over the average followup period of 6 months, for an incidence of 2.3 strokes per 100 patient-years. The number of patients who suffered a stroke and also had atrial fibrillation that was not treated with anticoagulation was not specified.

When compared with the stroke rate of approximately 5 per 100 patient-years reported for patients with nonrheumatic atrial fibrillation, the rate of stroke in patients with heart failure appears to be a somewhat lower, but clinically important, rate. [174-177] However, it is difficult to interpret the stroke incidence because many patients with heart failure have concomitant atrial fibrillation that predisposes them to stroke. The stroke rate may be higher in patients with worse functional status, although the incidence of bleeding complications could also be higher in this group.

The observed incidence of stroke in patients with heart failure must be compared with the reported incidence of major and minor bleeding complications resulting from anticoagulation. In recent randomized clinical trials, the risk of serious bleeding complications ranged from 0.8 to 2.5 percent per year in patients anticoagulated to prothrombin time ratios of 1.2-1.8. [174-177] However, the incidence of serious or fatal bleeding was not different from that observed in the controls. It is possible that patients with heart failure could have a higher incidence of complications due to intermittent hepatic congestion, which could impair warfarin metabolism.

Until there is evidence from RCT's, the dictum of "primum non nocere" ("first do no harm") suggests that patients with heart failure should not be anticoagulated unless they have atrial fibrillation or a history of systemic or pulmonary emboli. Patients with mobile left-ventricular thrombi on echocardiogram should be anticoagulated until the thrombus is no longer visible. Prothrombin times should be closely monitored, particularly during periods of exacerbations of heart failure when hepatic congestion may occur. Although patients with NYHA Class IV heart failure may benefit from anticoagulation even in the absence of the preceding indications, this practice cannot be advocated routinely until more data become available.

## Additional Pharmacological Management

Many patients with heart failure remain symptomatic despite the measures discussed earlier under "Initial Pharmacological Management." Others have comorbid conditions, such as angina or hypertension, which can adversely affect heart failure if not properly managed. This section addresses the management of these patients. Few controlled trials are available to provide guidance in these complex situations, so most recommendations derive from clinical experience. Although hypertension and angina can often be managed by primary care physicians, the treatment of patients with resistant heart failure is more complex, and the risks of treatment are greater.

If patients remain symptomatic on a combination of a diuretic, an ACE inhibitor, and digoxin, a consultation should be obtained with a practitioner who has expertise in the management of heart failure, if this has not been done previously. (Strength of Evidence = C.)

### Treatment of Persistent Heart Failure

Patients with persistent volume overload despite initial medical management may require more aggressive administration of the current diuretic (e.g., intravenous administration), more potent diuretics, or a combination of diuretics. (Strength of Evidence = C.)

In patients with persistent volume overload, furosemide can be increased to as much as 480 mg per day in divided doses, as discussed. Salt restriction should be reemphasized and compliance assessed and encouraged. Patients with persistent volume overload despite appropriate initial medical management may require additional measures to achieve diuresis. Several alternatives are available if additional measures are required (see Table 6 for agents and doses):

- Administer one or more doses of diuretic intravenously in an attempt to reduce any intestinal edema that may be impairing the absorption of orally administered loop diuretics.

- Administer a single dose of 2.5 mg of metolazone orally. Metolazone is extremely potent, and even a single dose can cause marked volume losses, hypotension, and hypokalemia. Patients who are treated with this therapy should be monitored carefully in the outpatient setting or admitted to the hospital. The combination of a loop diuretic and metolazone is extremely kaluretic, and almost all patients on this combination of drugs will require supplemental potassium. After the initial response is assessed, it can be decided whether dosing should be every third day, every other day, or every day. If necessary, the dose can be increased to 5-10 mg daily, with careful monitoring. Once adequate diuresis is achieved, it may be possible to reduce the dose of (or to discontinue) metolazone. Patients should be examined and electrolytes measured every third day during the initiation and titration of metolazone. Metolazone should not be used in the outpatient setting unless patients can be closely monitored for volume status, blood pressure, and electrolytes.

- Add spironolactone to loop diuretics and ACE inhibitors in patients with normal renal function and serum potassium levels. The usual dose of spironolactone is 25-50 mg twice per day. Because spironolactone is a potassium-sparing agent, potassium supplementation should be discontinued at the start of therapy. Because the combination of spironolactone and an ACE inhibitor may induce hyperkalemia, use of this combination of agents should be undertaken cautiously and with close observation. Potassium levels should be checked about every 3 days (depending on initial potassium level) until stable.

- Hospitalize the patient and institute intravenous inotropic therapy such as intravenous dobutamine to increase renal blood flow and facilitate diuresis.

Once a certain level of diuresis is reached, patients often do well on an oral diuretic alone, sometimes at reduced doses. Adjustment of diuretic dosage requires regular monitoring of blood pressure, serum sodium and potassium, and renal function. In general, patients should be reevaluated no later than 1 week after changing diuretics. Development of hyponatremia may require institution of fluid restriction. Potassium-sparing agents or supplemental potassium should be administered as needed to maintain serum potassium above approximately 4.0 mEq/L. If patients previously had their daily sodium intake restricted to 3 grams, the daily sodium intake should be decreased to 2 grams or less.

Patients with persistent dyspnea after optimal doses of diuretics, ACE inhibitors, and digoxin should be given a trial of hydralazine and/or nitrates. (Strength of Evidence = C.)

Hydralazine may be particularly useful in patients with persistent relative hypertension (i.e., diastolic blood pressure >110 mmHg) and in patients with evidence of severe mitral regurgitation. Alternatively, if a patient primarily has symptoms of pulmonary congestion or has a low systolic blood pressure, nitrates are preferred ( Table 2), such as isosorbide dinitrate, 40 mg TID. Topical nitroglycerin ointment may also be used, although its efficacy in heart failure has not been well documented. Nitroglycerin patches are probably inadequate. Oral nitrates should not be used more often than three times a day because of the problem of tachyphylaxis. [166] A 12-hour period between the evening dose and the morning dose is recommended. Patients who complain primarily of paroxysmal nocturnal dyspnea may be started on nitroglycerin ointment, 1 inch at bedtime. In addition, nitroglycerin tablets or spray often will alleviate transient symptoms of pulmonary congestion.

Beta-adrenergic blockers may improve functional status and natural history in patients with heart failure, but this form of treatment should be considered experimental therapy at this time. (Strength of Evidence = B.)

Many studies have examined the effect of metoprolol in patients with heart failure. [178-188] In an RCT of 383 patients with heart failure from idiopathic dilated cardiomyopathy, metoprolol treatment was associated with a trend toward reduction in the combined endpoint of mortality and need for heart transplantation. [185] There was a significant improvement in exercise capacity at 12 months. Existing data are inadequate to identify the population of patients in whom beta blockers may be safe and effective. Moreover, the effect of beta blockers on mortality has not been established. Thus, beta blockers should be considered an experimental, albeit promising, therapy.

### Angina and Heart Failure

Patients with heart failure and angina who will not or cannot undergo revascularization (see next section) should be treated with nitrates and aspirin. (Strength of Evidence = A.)

Because of their negative inotropic effect, calcium-channel blockers and beta blockers should be employed only by practitioners experienced in the use of these agents in patients with heart failure. (Strength of Evidence = C.)

Patients with heart failure and persistent angina who are not surgical candidates should be treated with long-acting nitrates, such as isosorbide dinitrate, in addition to aspirin. ACE inhibitors are not effective in reducing angina in patients with stable, exertional angina, [189] although they may decrease the incidence of recurrent MI or unstable angina. [15] Beta blockers must be used with caution because of their negative inotropic effect. Calcium channel blockers must be used with caution because of their negative inotropic effect and tendency to activate the renin-angiotensin and adrenergic nervous systems. Different calcium channel blockers may differ in the magnitude of these effects. Patients with heart failure and persistent angina despite nitrate therapy should consult with or be followed by a cardiologist.

### Persistent Hypertension Despite ACE Inhibitors and Diuretics

Persistent hypertension should be treated with a direct vasodilator, an alpha[sub 1]-adrenergic blocker, or a centrally acting alpha blocker. Because of their negative inotropic effect, calcium-channel blockers and beta blockers should be given only under the care of practitioners experienced in the use of these agents. (Strength of Evidence = C.)

Reduction of high blood pressure may in itself have a beneficial effect on the signs and symptoms of heart failure. Hypertension is a relative concept in patients with heart failure. Although a blood pressure of 135/85 mmHg may be acceptable for a patient with a normal EF, that same blood pressure may be harmful for a patient with severe left-ventricular systolic dysfunction. Some patients with heart failure will feel better when their blood pressure is low because their cardiac output is generally higher. Most patients will have some reduction in blood pressure with ACE inhibitors and diuretics, but some will remain hypertensive or have high-normal blood pressure. Additional diuresis may achieve some blood pressure reduction, and consideration should be given to increasing the dose of ACE inhibitors.

If additional antihypertensive treatment is necessary, direct vasodilators, alpha[sub 1]-adrenergic blockers or centrally acting alpha blockers should be used ( Table 7). Nitrates have only a small antihypertensive effect when blood pressure is elevated, although they frequently decrease blood pressure substantially in patients who are already marginally hypotensive. All calcium-channel blockers and beta blockers have a negative inotropic effect. As discussed previously, there is some evidence that patients with heart failure can tolerate beta blockers and have improved symptoms or functional status (see section on beta blockers), so these agents are not absolutely contraindicated. However, they must be used with extreme caution as antihypertensive agents, and they should only be used by practitioners with experience in the use of these agents for heart failure. See preceding discussion ("Angina and Heart Failure") regarding calcium channel blockers.

Table 7. Medications to Treat Hypertension or High-Normal Blood Pressure in Patients With Heart Failure

Drug | Initial Dose (mg) | Maximum Dose (mg) | Major Adverse Reactions
Direct Vasodilators
Hydralazine | 10 TID | 75 TID | Headache, nausea, dizziness, tachycardia, lupus-like syndrome.
Minoxidil | 2.5 QD | 80 QD | Fluid retention, hair growth, thrombocytopenia, leukopenia.
Alpha[sub 1]-Adrenergic Blockers
Doxazosin | 1 QD | 16 QD | Postural hypotension, dizziness, syncope, headache.
Terazosin | 1 QD | 20 QD | Postural hypotension, dizziness, syncope, headache.
Prazosin | 1 TID | 10 TID | Postural hypotension, dizziness, syncope, headache.
Centrally Acting Alpha Blockers
Clonidine tablets | 0.1 BID | 0.6 BID | Sedation, dry mouth, blurry vision, headache, bradycardia.
Clonidine patch | 0.1 weekly | 0.3 weekly | Same as clonidine; contact dermatitis.
Guanabenz | 4 BID | 64 BID | Similar to clonidine.
Guanfacine | 1 QD | 3 QD | Similar to clonidine.

Note:QD = once a day,BID = twice a day,TID = three times a day.