# Patient and Family Education and Counseling

## General Counseling

After a diagnosis of heart failure is established, patients and their families or caregivers should be counseled regarding the nature of heart failure, drug regimens, dietary restrictions, symptoms of worsening heart failure, what to do if these symptoms occur, and prognosis. The impact of heart failure on a patient's life may be related as much to psychological adaptation to the disease as to impairment in physical functioning. Nursing interventions, family involvement, and support groups may all help patients cope with heart failure. All patients should be encouraged to complete advance directives regarding their health care preferences. Practitioners should emphasize the importance of not smoking or chewing tobacco. Practitioners should recommend that patients receive vaccination against influenza and pneumococcal disease. (Strength of Evidence = C.)

It is vital that patients understand their condition and be involved in developing the plan for their care. Patients and their families should be encouraged to ask questions about any aspect of the management of heart failure and about any aspect of a recommended intervention. Patient and family education regarding any intervention should be designed to help patients arrive at realistic expectations about the outcome of an intervention. Patient and family education material and systems can be very useful to help clarify information and enhance understanding of heart failure and its management. A list of suggested topics for discussion is presented in Table 5.

Table 5. Suggested Topics for Patient, Family, and Caregiver Education and Counseling

General Counseling; - Explanation of heart failure and the reason for symptoms; - Cause or probable cause of heart failure; - Expected symptoms; - Symptoms of worsening heart failure; - What to do if symptoms worsen; - Self-monitoring with daily weights; - Explanation of treatment/care plan; - Clarification of patient's responsibilities; - Importance of cessation of tobacco use; - Role of family members or other caregivers in the treatment/care plan; - Availability and value of qualified local support group; - Importance of obtaining vaccinations against influenza and pneumococcal disease
Prognosis; - Life expectancy; - Advance directives; - Advice for family members in the event of sudden death
Activity Recommendations; - Recreation, leisure, and work activity; - Exercise; - Sex, sexual difficulties, and coping strategies
Dietary Recommendations; - Sodium restriction; - Avoidance of excessive fluid intake; - Fluid restriction (if required); - Alcohol restriction
Medications; - Effects of medications on quality of life and survival; - Dosing; - Likely side effects and what to do if they occur; - Coping mechanisms for complicated medical regimens; - Availability of lower cost medications or financial assistance
Importance of Compliance With the Treatment/Care Plan

It is impossible for patients to absorb all necessary information in one session. For patients who have been hospitalized, it is important to discuss medications and diet before discharge from the hospital and to repeat this information in the outpatient setting. This will allow patients time to assimilate the information and to formulate more questions. Because of the large number and often specialized nature of topics that are important to discuss with heart failure patients, practitioners should seek the assistance of dieticians, nurse educators, clinical nurse specialists, pharmacists, and support groups as part of a team approach to providing patient education. Visiting or home health nurses can be especially useful.

Finally, providers should be sensitive to differences in language and culture that may impair patients' understanding and compliance. Concerted attempts should be made to mitigate the influence of these factors.

The typical symptoms of worsening heart failure (orthopnea, paroxysmal dyspnea, leg edema, or exercise intolerance) should be explained, and patients should be advised to contact their doctor or nurse if such symptoms develop. All patients should also be told to obtain a bathroom scale and to weigh themselves each morning (after urinating and before eating). They should contact their provider if their weight has changed by more than 3-5 pounds since their last clinical evaluation. If patients know the symptoms and signs of worsening heart failure, they may be able to seek care early and avoid hospitalization. In addition, in compliant patients a diuretic regimen that the patient adjusts on the basis of weights taken at home can be a useful method for preventing decompensation and hospitalization.

An explanation of what patients can expect to experience will help avoid anxiety over symptoms and prevent patients from becoming afraid to perform daily activities that might provoke shortness of breath. Patients should be advised to stay as active as possible, as described in the section on activity recommendations. However, patients should understand that they may feel tired the following day if they overexert themselves. Sexual difficulties are common in these patients, and part of this arises from fear that exertion is detrimental. Sexual practices might need to be modified to accommodate patients with limited exercise tolerance. The practitioner should not expect the patient to bring up these issues; when appropriate, these topics should be discussed directly and openly.

Patients with heart failure must understand the serious implications of this diagnosis. Patients must be provided with accurate information in order to make decisions and plans for the future (see subsequent section on discussion of prognosis). At the same time, it is important to maintain hope and morale. Psychological factors may be more important to patients' quality of life and social functioning than the degree of physiologic impairment. [94, 95] Clinical nurse specialists, educators, family members, other caregivers, and qualified local support groups can all play an important role in optimizing patients' functioning and quality of life.

## Activity Recommendations

Regular exercise such as walking or cycling should be encouraged for all patients with stable NYHA Class I-III heart failure.[a] (Strength of Evidence = B.)

There is insufficient evidence at this time to recommend the routine use of supervised rehabilitation programs for patients with heart failure, although such programs may be of benefit to patients who are anxious; are dyspneic at a low work level; or have angina, a recent MI, or a recent CABG. (Strength of Evidence = C.)

Until the past few years, reduced activities and bed rest were considered a standard part of the care of patients with heart failure. [96] Although this practice may promote diuresis in the short term, it may also carry important risks and have a long-term detrimental effect on physical functioning. [97] Even short periods of bed rest result in reduced exercise tolerance and aerobic capacity [98-100] as well as muscular atrophy and weakness. [99, 101] Recent studies show that patients with heart failure can exercise safely, and regular exercise may improve functional status and decrease symptoms. [102-106] Neurohormonal activation is also diminished by a regular home exercise program. [107] Moreover, there is no evidence that exercise negatively affects the natural history of heart failure, with the possible exception of patients with acute myocarditis or a recent MI, who may be harmed by exercise. [108, 109]

The clinical improvement that occurs with exercise training programs probably results from effects on skeletal muscle rather than changes in myocardial function. [106, 110-112] Lactate production at submaximal exercise levels is reduced after training. Bicycle ergometry and arm ergometry have both been used for training programs, and Coats et al. have shown improvements with an unsupervised home cycling program. [102] There is insufficient evidence to recommend a specific type of training program or the routine use of supervised rehabilitation programs. However, such programs may benefit patients who are anxious about exercising; are dyspneic at a low work level; or have stable angina, a recent MI, or a recent CABG. In addition, supervised rehabilitation programs can provide patient and family counseling, regular encouragement and interpersonal contact, and assistance with facilitating patient compliance with treatment recommendations.

The NYHA classification is a four-level scheme for grading the functional incapacity of patients with cardiac disease. NYHA levels can be described as follows: I-Cardiac disease without resulting limitations of physical activity; II-Slight limitation of physical activity-comfortable at rest, but ordinary physical activity results in fatigue, palpitation, dyspnea, or anginal pain; III-Marked limitation in physical activity-comfortable at rest, but less than ordinary physical activity causes fatigue, palpitation, dyspnea, or anginal pain; IV-Inability to carry on any physical activity without discomfort or symptoms at rest. Although criticized for a lack of reliability, this system is still widely used.

## Dietary Recommendations

Dietary sodium should be restricted to as close to 2 grams per day as possible. In no case should sodium intake exceed 3 grams daily. (Strength of Evidence = C.)

Alcohol use should be discouraged. Patients who drink alcohol should be advised to consume no more than one drink per day. (Strength of Evidence = C.)

Patients with heart failure should be advised to avoid excessive fluid intake. However, fluid restriction is not advisable unless patients develop hyponatremia. (Strength of Evidence = C.)

Although a reduced-sodium diet has been a mainstay in managing heart failure, no studies have evaluated a specific dietary sodium restriction. [113-121] Thus, it is not clear from the literature whether mild sodium restriction (3 grams per day) is adequate for most patients or whether moderate restriction (2 grams per day) is beneficial. A 2-gram sodium diet is unpalatable for most patients, and the cost of low-sodium foods can be a burden for some patients. [118] This may lead to noncompliance, which is a major factor precipitating hospital admission for heart failure (see below). However, if dietary salt intake is excessive, diuretic dosing may be complicated or excessive, and potassium wasting may be exacerbated. [122]

A 3-gram sodium diet may be a reasonable and realistic target for patients with mild-to-moderate heart failure. This level of sodium intake can be achieved fairly easily by not adding salt to foods and avoiding salty foods. [120] However, many elderly patients may find even a 3-gram sodium diet unpalatable. Counseling and flexibility may be needed to promote compliance and to ensure that patients do not become malnourished. Patients who require high doses of diuretics will need to reduce their daily sodium intake to 2 grams or less. Avoiding processed foods and milk products (e.g., cheese) can reduce daily sodium intake to as little as 1 gram. [114]

All heart failure patients should receive specific dietary guidelines. Referral to a dietician, clinical nurse specialist, or nurse practitioner for dietary education and counseling is recommended. Handouts and educational guides are often inadequate for patients with reading difficulties and patients from ethnic groups with different food preferences. In all cases, it is essential to involve the spouse and family in educational efforts concerning the importance of diet and salt restrictions. In some cases, family recipes and menus may need to be altered in order to facilitate compliance with salt restrictions.

Acute ingestion of alcohol depresses myocardial contractility in patients with known cardiac disease. [123, 124 This may be clinically significant in patients with heart failure, although there are no studies that address this issue. Complete abstention from alcohol is crucial for patients with alcohol-induced cardiomyopathy. 91-93] For patients without a history of alcoholism, it is unclear whether abstinence makes a difference in functional status or mortality. In general, alcohol use should be discouraged. If patients want to continue to drink, they should be strongly advised to have no more than one drink per day. One drink equals a glass of beer or wine, or a mixed drink or cocktail containing no more than 1 ounce of alcohol.

Other dietary restrictions should be discouraged unless clearly indicated (e.g., a low-fat, low-cholesterol diet for severe hypercholesterolemia). Many patients with severe heart failure suffer from a syndrome of chronic wasting, referred to as "cardiac cachexia," that may be exacerbated by unnecessary dietary restrictions. Vitamin supplementation may be advisable because of water-soluble vitamin loss associated with diuresis and problems with gastrointestinal absorption of fat-soluble vitamins.

## Discussion of Prognosis

Patient counseling with respect to prognosis should be guided by recent trials [10, 18, 19, 125] and the Framingham experience, [126] which indicate that the average annual mortality rate for patients with heart failure is approximately 10 percent per year. For patient subgroups, the following estimates of mortality rates per year can be made: NYHA Class II, 5-10 percent; NYHA Class III, 10-20 percent; NYHA Class IV, 20-50 percent.

These studies may overestimate the mortality rates for the general population of patients with heart failure. In a recent study from the Mayo Clinic, it was found that the heart failure patients from a population-based cohort had a lower mortality rate than patients who were followed at the Mayo Clinic, suggesting a referral bias. [127] The population-based cohort with EF's less than 35 percent had a mortality rate of approximately 5 percent per year.

Within each NYHA class, the presence of more severe symptoms, progressive symptoms, or accompanying angina would push these estimates to the higher end of the range; conversely, milder symptoms, clinical stability, and absence of angina would shift the estimate to the lower end. As many as half of all cardiac deaths are sudden, and up to 25 percent of all deaths occur without significant worsening of heart failure. [10, 18, 126]

It is vital that patients receive accurate information concerning prognosis in order to make decisions and plans for the future. Practitioners should discuss patients' desires regarding resuscitation, and all patients should be encouraged to complete a durable power of attorney for health care or another form of advance directive.

If a patient desires resuscitation, family members should consider learning cardiopulmonary resuscitation. Such a course should be combined with psychosocial support for patients and family members because it may otherwise have negative psychological consequences. [128] If a patient decides that resuscitation is not desired, it is crucial to discuss with family members or caretakers what to do in the event of sudden death. If paramedics are called, a chain of events is likely to take place that may be difficult to control and contrary to the patient's wishes. A call to 911 is often a reflex response to a loved one's death. Instead, when resuscitation is not desired, family members or other caregivers should be instructed to call a doctor, nurse, hospice worker, or other designated responsible individual.

## The Problem of Noncompliance

Because noncompliance is a major cause of morbidity and unnecessary hospital admissions in heart failure, the use of educational programs or support groups should be a routine part of the care of patients with heart failure. Noncompliance may reduce life expectancy and is also a major cause of hospitalizations. Practitioners should be attuned to the problem of noncompliance and its causes and should discuss the importance of compliance at followup visits and assist patients in removing barriers to compliance (e.g., cost, side effects, or complexity of the medical treatment regimen). (Strength of Evidence = B.)

Noncompliance is an important problem with any chronic disease, and heart failure is no exception. [64, 129] Noncompliance may reduce life expectancy (e.g., when patients fail to take beneficial medications) and may also be a major cause of hospitalizations. Ghali et al. found a 54-percent rate of noncompliance with diet or medications, and noncompliance was the most common factor precipitating readmission. [129] Vinson et al. found that 27 percent of 140 patients hospitalized for heart failure were rehospitalized within 90 days of discharge and 27 percent were rehospitalized at least once for recurrent heart failure. [64] Twenty-two separate admissions were subjectively judged to have resulted from medication or dietary noncompliance. Readmissions for heart failure could be substantially reduced if compliance were improved.

Although it is clear that noncompliance is a major problem in caring for patients with heart failure, it is less clear what should be done to improve this situation. Rosenberg evaluated the impact of a coordinated team approach to planning, education, and supervision on dietary compliance and readmission rates. [66] Patient-directed group meetings were at the core of the program. Dietary compliance was improved, and hospital admissions were reduced from 46 to 12 percent compared with the previous year and from 31 to 17 percent compared with a control group of patients at another hospital. These results are very encouraging because group programs can provide a more cost-effective intervention than one-on-one teaching. The group process may have other therapeutic aspects besides its educational component. Meta-analyses of educational programs for other chronic diseases also support their value in improving compliance and outcomes. [130, 131] Educational programs or qualified local support groups should be a routine part of the treatment and care of patients with heart failure. Physicians and other practitioners should be aware of the problem of noncompliance and its causes and should reinforce the importance of compliance at routine visits. In addition, although not tested in heart failure patients, effective interventions to promote compliance in hypertensives and patients with coronary artery disease have included family involvement in care and the use of patient contracts. Similar techniques may prove effective in the context of heart failure.