# Assessment of Left-Ventricular Function

Patients with suspected heart failure should undergo echocardiography or radionuclide ventriculography to measure EF (if information about ventricular function is not available from previous tests). (Strength of Evidence = B.)

Measurement of left-ventricular performance is a critical step in the evaluation and management of almost all patients with suspected or clinically evident heart failure. The combined use of history, physical examination, chest x-ray, and electrocardiography cannot be relied on to distinguish between the major etiologies of heart failure: left-ventricular systolic dysfunction (i.e., EF < 35-40 percent), left-ventricular diastolic dysfunction (i.e., heart failure occurring despite EF ≥40 percent), valvular heart failure disease, or a noncardiac etiology. A substantial proportion (up to 40 percent in some studies) of patients with signs and symptoms of heart failure have EF's greater than 50 percent. [26, 29, 30, 68, 69] These patients generally have valvular disease, intermittent ischemia, or ventricular diastolic dysfunction. If measurement of ventricular performance is not obtained in these patients, inappropriate treatments may be instituted (e.g., digoxin, which has not been shown to be effective in patients with normal ventricular systolic function). [69]

Echocardiography or radionuclide ventriculography can substantially improve diagnostic accuracy in distinguishing between systolic and diastolic dysfunction. [27, 29, 30, 69-75]

Patients whose symptoms are fully accounted for by an underlying noncardiac condition (see above) or who have previously documented decreased ventricular performance (e.g., recent echocardiogram or contrast ventriculogram) do not require determination of EF.

Although elderly patients with mild symptoms are often managed without measurement of ventricular performance, this practice is discouraged for the following reasons:

- The elderly are the very individuals in whom it may be most difficult to make the diagnosis of heart failure and to determine whether failure is due to systolic or diastolic dysfunction.
- Although mild diuretic therapy may cause little harm in patients with fluid retention of any etiology, use of other medications-such as ACE inhibitors, digoxin, or nitrates-has significant risks and no established benefit unless they are specifically indicated. These agents may even worsen the condition of patients with heart failure secondary to left-ventricular diastolic dysfunction.

Both echocardiography and radionuclide ventriculography are appropriate measures for the evaluation of left-ventricular performance. Although EF measured by radionuclide ventriculography may have a higher correlation with cineangiography than that measured by echocardiography (r = 0.88 versus r = 0.78, respectively), [76] echocardiography has good reproducibility (r = 0.89) [77] and accuracy for measuring EF (r = 0.78-0.89). [76-78] The use of quantitative techniques has been found to improve measurement of EF in some studies. [66, 78] However, Stamm et al. found that real-time estimation by the echocardiographer was more accurate than any of several algorithms tested. [77]

In general, the panel considered echocardiography to be the preferred test because of its ability to assess valvular function and left-ventricular hypertrophy, but selection of a diagnostic test should depend on the capabilities of individual clinical centers. Between 8 and 18 percent of patients will have technically inadequate echocardiograms, in which case radionuclide ventriculography should be performed. [79-81]

Although there are no studies in the literature on the quality of echocardiography and radionuclide ventriculography in community practice, the panel perceives significant quality problems in the performance and interpretation of both tests. When referred to a specialist, patients should be encouraged to bring a video of the actual images of their echocardiogram with them, rather than a written report. In this way, the quality of the study can be determined directly. Advantages and disadvantages of echocardiography and radionuclide ventriculography are summarized in Table 4.

Table 4. Echocardiography and Radionuclide Ventriculography Compared in Evaluation of Left-Ventricular Performance

Test | Advantages | Disadvantages
Echocardiogram | Permits concomitant assessment of valvular disease, left-ventricular hypertrophy, and left-atrial size Less expensive than radionuclide ventriculography in most areas Able to detect pericardial effusion and ventricular thrombus More generally available | Difficult to perform in patients with lung disease Usually only semi-quantitative estimate of ejection fraction provided Technically inadequate in up to 18% of patients under optimal circumstances
Radionuclide ventriculogram | More precise and reliable measurement of EF Better assessment of right-ventricular function | Requires venipuncture and radiation exposure Limited assessment of valvular heart disease and left-ventricular hypertrophy

It is important to note that although echocardiography or radionuclide ventriculography is essential for determining the presence and degree of left-ventricular dysfunction, these tests are less useful in determining the etiology of that dysfunction. Specifically, the presence or absence of regional wall motion abnormalities is of limited value in determining whether a patient's disease is due to coronary artery disease or to idiopathic dilated cardiomyopathy. [79, 80, 82, 83] For example, Diaz et al. found that 56 percent of patients with idiopathic dilated cardiomyopathy had regional wall motion abnormalities rather than global hypokinesis. [80] Conversely, 35 percent of patients with coronary artery disease had global hypokinesis without regional wall motion abnormalities.

Similarly, right-ventricular dilatation is not helpful in distinguishing idiopathic dilated cardiomyopathy from ventricular dysfunction due to ischemia or prior MI. [80, 84] Thus, the findings from echocardiography or radionuclide ventriculography should not be used to determine the etiology of a patient's cardiomyopathy or the need for further evaluations of coronary artery disease, such as coronary artery angiography.

## Interpretation of Left-Ventricular Function Testing

The majority of patients with heart failure have moderate-to-severe left-ventricular systolic dysfunction and EF's of <35-40 percent. This guideline is directed at the management of such patients. However, patients with symptoms of heart failure and EF's greater than 40 percent may still have heart failure due to left-ventricular diastolic dysfunction, valvular disease, or pericardial disease. The majority of these etiologies will be discernible with echocardiography. A full discussion of the diagnosis and treatment of these conditions is beyond the scope of this guideline, although a few comments on diastolic dysfunction are necessary because of its high prevalence.

## Diastolic Dysfunction

As many as 40 percent of patients with a clinical diagnosis of heart failure have preserved left-ventricular systolic function and no evidence of valvular heart disease. [26, 29, 30, 68, 69] Most of these individuals have left-ventricular diastolic dysfunction. In these cases, the left ventricle has increased diastolic stiffness (reduced compliance) and cannot fill adequately at normal diastolic pressures. [85] The elevated pressures required for filling result in symptoms of pulmonary congestion. In addition, the reduced left-ventricular filling volume leads to lowered stroke volumes and symptoms of poor cardiac output.

Most diastolic dysfunction results from coronary artery disease or hypertension. Because ischemia can produce diastolic dysfunction before systolic dysfunction develops, physiologic testing for ischemia should be considered in patients with diastolic dysfunction, particularly when dyspnea on exertion is a prominent symptom. [85] Hypertension is also a common cause of diastolic dysfunction, [86-89] which can develop even in the absence of left-ventricular hypertrophy. [86, 90]

The optimal treatment of diastolic dysfunction is not well defined. For a full discussion, readers are referred to the recent review by Bonow and Udelson. [85] At this time, it appears that beta-blocking agents, calcium-channel blockers, and the judicious use of diuretics are the treatments of choice. Agents used to treat systolic dysfunction may be deleterious in patients with diastolic dysfunction. Excessive diuresis can reduce stroke volume and cardiac output. Digitalis may further decrease left-ventricular compliance. The role of ACE inhibitors is not clear. Vasodilators may be detrimental in diastolic dysfunction although ACE inhibitors may have beneficial effects by directly improving ventricular relaxation and causing regression of hypertrophy.

## Determination of Specific Etiologies for Left-Ventricular Systolic Dysfunction

Once left-ventricular dysfunction is confirmed, the results of the history and physical examination should be reviewed to search for clues to potentially treatable causes of heart failure. Additional information should be sought as appropriate. Clinicians should follow up any positive findings with appropriate laboratory testing. Routine use of myocardial biopsy is not warranted. (Strength of Evidence = C.)

The most common causes of left-ventricular systolic dysfunction are coronary artery disease, idiopathic dilated cardiomyopathy, hypertension, and alcohol abuse. The most common potentially reversible cause of heart failure is myocardial ischemia. Therefore, patients should be carefully questioned concerning a history of chest pain or recurring episodes of sudden pulmonary edema suggestive of ischemia. Evaluation of patients with angina is discussed subsequently in the section on revascularization. Alcoholism is important to detect and treat because alcohol may aggravate cardiac dysfunction. [91-93] Where appropriate, patients should also be asked about cocaine use, and a urine test for cocaine may be helpful in selected patients. Specific treatable etiologies (e.g., sarcoidosis) should be considered when the constellation of systemic findings suggests a diagnosis. Patients with a history of liver disease, unexplained hepatomegaly, diabetes or other endocrine dysfunction, or bronze discoloration of the skin should be evaluated for hemochromatosis with a serum iron level, total iron binding capacity, and ferritin level. An exhaustive search for the etiology of heart failure in a patient without specific findings on history and physical examination is of little value.