# Initial Evaluation

Note: Figure 2 shows the content and organization of this chapter.

Figure 2. Initial Evaluation of Patients With Heart Failure

## Symptoms Suggestive of Heart Failure

All patients who complain of paroxysmal nocturnal dyspnea (awakening from sleep with shortness of breath), orthopnea (shortness of breath upon lying down), or new-onset dyspnea on exertion should undergo evaluation for heart failure unless history and physical examination clearly indicate a noncardiac cause for their symptoms, such as severe pulmonary disease. (Strength of Evidence = B.)

Symptoms suggestive of heart failure include the following:

- Paroxysmal nocturnal dyspnea.
- Orthopnea.
- Dyspnea on exertion.
- Lower extremity edema.
- Decreased exercise tolerance.
- Unexplained confusion, altered mental status, or fatigue in an elderly patient.
- Abdominal symptoms associated with ascites and/or hepatic engorgement (e.g., nausea or abdominal pain).

Many patients with severely impaired left-ventricular function have no symptoms of heart failure. Marantz et al. reported that 20 percent of patients with EF's less than 40 percent met no clinical criteria for heart failure, [26] and Mattleman et al. found that only 42 percent of patients with left-ventricular EF's less than 30 percent had dyspnea on exertion. [27]

When clinical heart failure develops, dyspnea on exertion appears to be the earliest symptom. In a study of patients with known coronary disease undergoing coronary artery angiography, two-thirds of patients with elevated pulmonary capillary wedge pressures had dyspnea on exertion. [28] Only 31 percent had paroxysmal nocturnal dyspnea, 23 percent had a history of leg edema, and 21 percent had orthopnea. However, many patients with normal pulmonary capillary wedge pressures also had dyspnea on exertion (specificity: 52 percent), whereas the other symptoms were unusual unless the wedge pressure was elevated (specificity: 76-81 percent).

Although the presence of any one of the symptoms listed above is sufficient to warrant consideration of heart failure as the underlying cause, orthopnea, paroxysmal nocturnal dyspnea, and progressive dyspnea on exertion are of greatest concern. The other symptoms listed above are less likely to represent heart failure if they occur in isolation. A history of previous MI, poorly controlled hypertension, or other heart disease,

It is important to note that the symptoms listed above are not always due to heart failure. Dyspnea (whether at rest or on exertion) can be caused by a wide range of conditions, including most pulmonary diseases, obesity, deconditioning, volume overload from nephrotic syndrome or renal failure, intermittent cardiac ischemia, anxiety, and acute lower respiratory infections. Patients with these conditions may not require evaluation for heart failure unless the symptoms are more severe than can be accounted for on the basis of those conditions.

Dyspnea on exertion is particularly common in patients with COPD, interstitial lung disease, chronic pulmonary thromboembolic disease, and primary pulmonary hypertension. It is usually possible to distinguish between cardiac and pulmonary causes of dyspnea on the basis of history, physical examination, and chest x-ray.

Absence of cardiomegaly on chest x-ray weighs against the diagnosis of heart failure due to systolic dysfunction except when pulmonary hyperinflation may mask an enlarged heart. [29, 30] Patients with evident pulmonary disease generally do not require a full evaluation for heart failure unless their symptoms are out of proportion to the severity of their lung disease.

In addition to obtaining information about symptoms suggestive of heart failure, it is important that a complete medical history be obtained during the initial evaluation. In particular, information should be sought concerning previous MI; angina or equivalent (e.g., flash pulmonary edema); diabetes; renal, pulmonary, thyroid, or gastrointestinal disease; and medications.

## Physical Examination

The physical examination can provide important information about the etiology of patients' symptoms and about appropriate initial treatment. However, physical signs are not highly sensitive for detecting heart failure. Therefore, patients with symptoms that are highly suggestive of heart failure should undergo echocardiography or radionuclide ventriculography to measure EF even if physical signs of heart failure are absent. (Strength of Evidence = C.)

Conversely, many physical findings of heart failure are not highly specific. Elevated jugular venous pressure, a third heart sound, and a laterally displaced apical impulse are the most specific and are virtually diagnostic in a patient with compatible symptoms. Pulmonary rales or peripheral edema are relatively nonspecific findings, however. The presence of these signs, therefore, does not require measurement of EF if other symptoms, signs, and radiographic findings of heart failure are absent. (Strength of Evidence = B.)

The initial workup of patients with symptoms suggestive of heart failure begins with a careful physical examination.Abnormal physical findings that tend to support a diagnosis of heart failure include the following:

- Elevated jugular venous pressure or positive hepatojugular reflux.
- A third heart sound.
- Laterally displaced apical impulse.
- Pulmonary rales that do not clear with cough.
- Peripheral edema not due to venous insufficiency.

Many patients with moderate-to-severe left-ventricular systolic dysfunction or early symptoms of heart failure have no physical findings. The most sensitive physical finding is the third heart sound. A third heart sound was found in 68 percent of patients with EF's below 30 percent. [27] Rales and a displaced apical impulse were present in only 37 and 42 percent of patients, respectively. Jugular venous distention and peripheral edema appear to be the least sensitive signs. [28] Studies of patients with severe heart failure undergoing cardiac catheterization before transplantation have also shown that physical findings are frequently absent even in patients with pulmonary capillary wedge pressures as high as 35 mmHg. [31]

The specificity of physical findings is less well defined because this has not been studied in a patient population without known or suspected heart disease. Elevated jugular venous pressure (as manifested by elevated jugular vein pulsations) and third heart sound are the most specific signs of heart failure. Rales in a patient with compatible symptoms and no known pulmonary disease are highly suggestive of heart failure. Lower extremity edema is a relatively nonspecific finding common in patients without heart failure. The most common cause of peripheral edema is venous insufficiency, not heart failure. Other causes of lower leg edema include lymphatic obstruction, conditions associated with hypoalbuminemia, deep venous thrombosis, and treatment with a calcium-channel blocker. [31, 32] Leg edema is unlikely to be caused by heart failure if there is no elevation in the jugular venous pressure and no orthopnea, paroxysmal nocturnal dyspnea, or dyspnea on exertion.

As mentioned, physical examination findings may not be highly sensitive indicators of heart failure. Some patients with heart failure do not manifest any of these signs, so the absence of physical findings should not dissuade the clinician from undertaking a thorough evaluation of patients with unexplained symptoms of heart failure. [31, 32] Care must be taken in assessing clinical signs of heart failure, because several studies suggest that intra- and interrater reliability of physical signs is often lower than would be desirable. [33, 34]

## Diagnostic Testing

Practitioners should perform a chest x-ray; ECG; complete blood count (CBC); serum electrolytes, serum creatinine, serum albumin, liver function tests; and urinalysis for all patients with suspected or clinically evident heart failure. A T4 and thyroid-stimulating hormone (TSH) level should also be checked in all patients over the age of 65 with heart failure and no obvious etiology and in patients who have atrial fibrillation or other signs or symptoms of thyroid disease. (Strength of Evidence = C.)

A chest x-ray should be obtained as an early diagnostic test. Cardiomegaly in symptomatic patients is highly suggestive of heart failure, especially when accompanied by pulmonary venous congestion. [27, 29, 30] As discussed earlier, a normal chest x-ray weighs against a diagnosis of heart failure but does not rule it out. Besides helping to distinguish cardiac from pulmonary causes of dyspnea, chest x-rays can also provide information concerning pulmonary disease, calcified heart valves, left-atrial size, and right-ventricular versus left-ventricular enlargement.

An ECG should also be performed. Among the possible findings of interest are acute ischemia, arrhythmias, prior MI, left-ventricular hypertrophy, and conduction abnormalities. However, the ECG is usually nonspecific in patients with heart failure. [35]

In some patients it may be difficult to distinguish between symptoms due to cardiac and pulmonary dysfunction. Screening spirometry may be helpful in these cases, although measurement of EF may be equally (or more) illuminating.

An initial exercise test may occasionally be useful to determine a patient's exercise tolerance when the history regarding dyspnea on exertion is difficult to evaluate. This situation can occur in patients who (1) are sedentary, (2) are unable to provide an accurate history, (3) usually deny or minimize symptoms, or (4) have histories that conflict with those of family members. Patients with unexplained decreases in exercise tolerance without apparent cause should also be evaluated for heart failure.

A search for precipitating, complicating, or primary causative factors should be undertaken in every patient with suspected new-onset heart failure. Table 3 summarizes the tests that should generally be undertaken to assess patients with symptoms or signs of heart failure, including possible findings and suspected diagnosis. Routine chemistry examinations (including serum electrolytes, blood urea nitrogen [BUN], and measures of renal and liver function) should be obtained on all patients for baseline purposes and to assist in subsequent decisionmaking regarding management (e.g., elevated potassium may preclude use of ACE inhibitors).

Table 3. Recommended Tests for Patients With Signs or Symptoms of Heart Failure

Test Recommendation | Finding | Suspected Diagnosis
Electrocardiogram | Acute ST-T wave changes Atrial fibrillation, other tachyarrhythmia | Myocardial ischemia Thyroid disease or heart failure due to rapid ventricular rate
| Bradyarrhythmias | Heart failure due to low heart rate
| Previous MI (e.g., Q waves) | Heart failure due to reduced left-ventricular performance
| Low voltage | Pericardial effusion
| Left-ventricular hypertrophy | Diastolic dysfunction
Complete blood count | Anemia | Heart failure due to or aggravated by decreased oxygen-carrying capacity
Urinalysis | Proteinuria | Nephrotic syndrome
| Red blood cells or cellular casts | Glomerulonephritis
Serum creatinine | Elevated | Volume overload due to renal failure
Serum albumin | Decreased | Increased extravascular volume due to hypoalbuminemia
T4 and TSH (obtain only if atrial fibrillation, evidence of thyroid disease, or patient age >65) | Abnormal T4 or TSH | Heart failure due to or aggravated by hypo/hyperthyroidism

Note: TSH = Thyroid-stimulating hormone, MI = myocardial infraction.

Probably the most common complicating factor for heart failure is hypertension. In patients with hypertension and clinically evident heart failure, every effort should be made to control blood pressure.

Hematocrits of 25-35 percent may aggravate underlying heart failure; patients with anemia in this range should be managed as appropriate (e.g., with iron supplements for patients with iron deficiency anemia, or with transfusion if there is evidence of ongoing ischemia) while receiving continued evaluation and management of their heart failure. Hematocrits below 25 percent can produce signs and symptoms of heart failure without underlying cardiac abnormalities; patients with anemia in this range should be reevaluated after correction of anemia to determine whether additional workup for heart failure is required. Extreme caution should be exercised if transfusion becomes necessary, as this process may exacerbate symptoms of heart failure. Use of packed red blood cells is recommended when transfusion is necessary.

Renal insufficiency or failure may cause volume overload that mimics heart failure or exacerbates underlying left-ventricular dysfunction. These patients should generally be treated with diuretics or dialysis and reassessed after correction of volume overload to determine whether further evaluation for heart failure is necessary. Decreased serum albumin may also mimic or exacerbate heart failure.

### Screening for Arrhythmias

Screening evaluation for arrhythmias, such as ambulatory electrocardiographic (Holter) recording, is not routinely warranted. (Strength of Evidence = A.)

Patients with a history of syncope possibly due to ventricular arrhythmias should be referred immediately to a practitioner with expertise in arrhythmias. (Strength of Evidence = C.)

A full discussion of the treatment of arrhythmias in patients with heart failure is beyond the scope of this guideline, which addresses only the issue of screening for arrhythmias. Ventricular arrhythmias are common in patients with heart failure, and death is sudden in up to half of patients. [19, 36, 37] Patients with nonsustained ventricular tachycardia, as identified by ambulatory electrocardiographic monitoring, have a worse prognosis than patients without this finding. [38] However, the observed increase in mortality is due in part to an increased rate of death from heart failure. [39] Thus, for an individual patient, the finding of frequent premature ventricular depolarizations or nonsustained ventricular tachycardia may be a poor predictor of sudden death. Arnsdorf and Bump concluded that ambulatory ECG monitoring helps define the average risk of death in a group of people but is of limited value in defining the risk for the individual patient. [36] Even if a high-risk group could be accurately identified, there is no treatment available at this time that has been shown to decrease the mortality rate of patients with asymptomatic, nonsustained ventricular tachycardia. Studies of amiodarone in this setting have shown conflicting results. [40-44] A large, placebo-controlled trial was scheduled for completion in March 1994.

Patients with heart failure should be questioned about symptoms suggestive of sustained ventricular tachycardia, such as syncope or near syncope. Patients with these symptoms should be referred immediately to a practitioner with expertise in the management of arrhythmias. Patients lacking such symptoms should not be subjected to a search for arrhythmias using ambulatory ECG recording. Such testing will often detect less serious forms of ventricular ectopy, including premature ventricular contractions. [45-51] These findings are often worrisome to both the patient and clinician and may provoke physicians into using antiarrhythmic agents that have no proven value and carry a significant risk of proarrhythmic effects and death. Antiarrhythmic drugs worsen arrhythmias in 5-20 percent of patients with normal left-ventricular function, [52-57] and patients with left-ventricular dysfunction are at higher risk for this effect. [58-60] The Cardiac Arrhythmia Suppression Trial [61, 62] found an increased mortality rate in patients with EF's of 40 percent or less and six or more ventricular premature depolarizations per hour and who were treated with the antiarrhythmic agents moricizine, [61] encainide, [62] and flecainide. [62] These findings raise serious concerns about treating all but the most serious arrhythmias in patients with left-ventricular dysfunction.

### Atrial Fibrillation

Atrial fibrillation is present in 10-15 percent of patients with heart failure. 18, 19 It may occur in up to 50 percent of patients with more severe heart failure. [10] If atrial fibrillation causes sudden, severe worsening of heart failure, immediate cardioversion may be necessary. However, most patients can be stabilized by using digoxin to control the heart rate. Once stable, all patients should be considered for cardioversion.

Patients with left-atrial diameters of less than 50 mm and less than a 1-year history of atrial fibrillation should be cardioverted. Patients should be anticoagulated for 3 weeks before cardioversion. (Strength of Evidence = C.)

Because of the risks of antiarrhythmic drugs, electrical cardioversion is probably the preferred therapy. If this is successful, patients should be continued on anticoagulants for 6-12 months and monitored for recurrence of atrial fibrillation. If atrial fibrillation recurs, then the risks and benefits of repeat cardioversion must be weighed again. If atrial fibrillation does not recur, then anticoagulation can be discontinued at the discretion of the clinician.

Patients with left-atrial diameters greater than 50 mm or with chronic atrial fibrillation for more than 1 year are unlikely to remain in sinus rhythm without antiarrhythmic therapy. Because the risk of provoking ventricular arrhythmias with type I antiarrhythmic drugs is increased in patients with heart failure, patients should be placed on these agents only if there are clear-cut benefits from the resumption of sinus rhythm (i.e., improved hemodynamics or decreased risk of embolism in a patient with contraindications to chronic anticoagulation). Amiodarone may be the preferred agent. If a patient tolerates the atrial fibrillation well, has no contraindication to anticoagulation, and is unlikely to remain in sinus rhythm without antiarrhythmic drugs, it may be best to allow the patient to remain in atrial fibrillation and to start anticoagulation.

## Hospital Admission and Discharge Criteria

The presence or suspicion of heart failure and any of the following findings usually indicates a need for hospitalization. (Strength of Evidence = C.)

- Clinical or electrocardiographic evidence of acute myocardial ischemia.
- Pulmonary edema or severe respiratory distress.
- Oxygen saturation below 90 percent (not due to pulmonary disease).
- Severe complicating medical illness (e.g., pneumonia).
- Anasarca.
- Symptomatic hypotension or syncope.
- Heart failure refractory to outpatient therapy.
- Inadequate social support for safe outpatient management.

Most of the guideline's evaluation and care recommendations can be accomplished in either an inpatient or outpatient setting. The guideline does not address strategies specific to inpatient settings (e.g., pulmonary artery catheter, cardiac assist devices) but does make some statements concerning the transition between outpatient management and inpatient care.

Specifically, practitioners should be aware of the appropriate indications for hospitalization and for discharge from hospital. The above recommendations are made in the absence of specific data, although studies of predictors of hospital mortality were useful in formulating these recommendations. [6, 8, 63] Some patients with the above findings may be managed at home or in an assisted living or nursing home setting if, in the physician's carefully considered opinion, it is safe to do so and adequate outpatient monitoring and followup visits can be arranged.

Patients with heart failure should be discharged from the hospital only when (Strength of Evidence = C):

- Symptoms of heart failure have been adequately controlled.
- All reversible causes of morbidity have been treated or stabilized.
- Patients and caregivers have been educated about medications, diet, activity and exercise recommendations, and symptoms of worsening heart failure.
- Adequate outpatient support and followup care have been arranged.

Proper discharge planning is an essential component of managing patients with heart failure. Heart failure is one of the most common causes for recurrent admission to hospitals, and many of these admissions may be avoidable. Readmission rates as high as 57 percent within 90 days have been reported in patients over the age of 70 years. [64] Vinson et al. found that the factors associated with readmission to hospitals were: failed social support systems (21 percent), inadequate followup (20 percent), failure to seek medical attention promptly when symptoms recurred (20 percent), noncompliance with diet (18 percent), noncompliance with medication (15 percent), and inadequate discharge planning (15 percent). [64] Gooding and Jette found that 36 percent of 147 patients were readmitted within 6 months. [65] Patients were more likely to be readmitted if the initial discharge site was home rather than a secondary facility (39 and 19 percent, respectively). These authors highlighted the importance of securing compliance for medication and dietary regimens and called for better home care after discharge and better coordination of care between secondary and primary care providers.

Rosenberg demonstrated that better patient education decreased hospital admissions for patients with heart failure. [66] Perlman et al. demonstrated that public health nurses could detect deterioration in heart failure at a stage early enough to allow intervention that avoided admission to the hospital. [67] Patients should usually have a followup contact within 7 days after discharge to (1) make sure that medications are being taken properly, (2) assess compliance with reduced salt diet, (3) ensure that patient's weight is stable, (4) adjust the dosage of diuretics and other medications if necessary, and (5) determine that the patient, family, and caregivers understand when and how to contact the practitioner. Electrolytes, BUN, and creatinine should also be checked about 1 week following discharge, and medications adjusted as necessary.