# Prevention in Asymptomatic Patients

Asymptomatic patients who are found to have moderately or severely reduced left-ventricular systolic function (EF <35-40 percent) should be treated with an ACE inhibitor to reduce the chance of developing clinical heart failure. (Strength of Evidence = A.)

The prevention of clinically evident heart failure represents one of the most important opportunities for decreasing mortality and morbidity from this often fatal condition. The most effective preventive interventions are probably the treatment of hypertension and the prevention of MI through the reduction in risk factors for coronary vascular disease. Thrombolytic therapy to minimize the size of an MI and prevention of second infarctions are also important. A description of these interventions lies outside the scope of this guideline.

Even after patients have sustained an MI and developed moderate-to-severe left-ventricular systolic dysfunction, it is still possible to slow or prevent the progression to symptomatic heart failure. In the Survival and Ventricular Enlargement (SAVE) trial, patients with an MI in the preceding 3-16 days and EF's of 40 percent or less were treated with captopril titrated to 50 mg TID as tolerated. [15] Overall mortality during the 2- to 5-year study period (average followup: 42 months) was 20 percent in those treated with captopril, compared with 25 percent in those treated with placebo. The proportion of patients developing heart failure that required open-label treatment with ACE inhibitors was reduced from 16 to 11 percent, and the proportion of patients hospitalized for heart failure was reduced from 17 to 14 percent. The Cooperative New Scandinavian Enalapril Survival Study (CONSENSUS) II [25] found a reduction (from 30 to 27 percent) in the incidence of symptomatic heart failure when enalapril was used after MI, but no reduction in mortality was observed. However, the methods used in this study differed from those of other studies in that (1) early intravenous dosing was used post-MI, (2) therapy was not limited to patients with left-ventricular dysfunction, and (3) patients were followed for only 6 months postinfarction-a time when benefits in the SAVE study were only beginning to be apparent.

EF should be determined before discharge (e.g., 3-7 days post-MI) in patients following an MI to determine whether an ACE inhibitor would be beneficial. This may not be necessary, however, for patients at low risk for significant systolic dysfunction-that is, patients who meet all of the following criteria:

- No previous MI.
- Inferior infarction.
- Relatively small increase in cardiac enzymes (i.e., <2-4 times normal).
- No Q waves on ECG.
- Uncomplicated clinical course (e.g., no arrhythmias or hypotension).

Asymptomatic patients with moderate-to-severe left-ventricular dysfunction may also be discovered during the evaluation of other problems, such as a heart murmur or cardiomegaly on a chest x-ray. These patients may also benefit from ACE inhibitors. The Studies of Left-Ventricular Dysfunction (SOLVD) prevention trial found that enalapril (titrated to 10 mg BID) could reduce the development of symptomatic heart failure to 21 percent in asymptomatic patients, compared with 30 percent in those treated with placebo. [16] The average duration of followup was 3 years. No significant effects on total mortality or cardiovascular mortality were observed. These results are encouraging, but they do not justify screening asymptomatic patients for left-ventricular dysfunction unless they have a history of previous Q-wave MI and EF was not measured after the infarction. The majority of patients with asymptomatic left-ventricular dysfunction will have had a previous MI, and they may be taking aspirin or a beta blocker. Adding ACE inhibitors to these medications is generally safe and effective.