# Overview

## Introduction

On December 19, 1989, the Omnibus Budget Reconciliation Act (Public Law 101-239) added a new Title IX to the Public Health Service Act establishing the Agency for Health Care Policy and Research (AHCPR). AHCPR's goal is to enhance the quality, appropriateness, and effectiveness of health care services and access to such services. Section 911 of the Act establishes within AHCPR the Office of the Forum for Quality and Effectiveness in Health Care. Section 912 directs the Forum to facilitate the development and periodic review and updating of:

Clinically relevant guidelines that may be used by physicians, educators, and health care practitioners to assist in determining how diseases, disorders, and health care conditions can most effectively and appropriately be prevented, diagnosed, treated, and managed clinically.

Following this mandate, AHCPR selected heart failure as a topic for guideline development and as one of the first three guidelines to be developed under contract. Unlike the first seven guidelines, which were developed by private-sector panels convened directly by AHCPR, these contract guidelines were created by panels of experts and consumers selected (with the concurrence of AHCPR) and staffed by a private contracting organization. In the case of the heart failure guideline, the contracting agency was RAND, a nonprofit public policy and research organization in Santa Monica, California.

Heart failure is a clinical syndrome or condition characterized by (1) signs and symptoms of intravascular and interstitial volume overload, including shortness of breath, rales, and edema, or (2) manifestations of inadequate tissue perfusion, such as fatigue or poor exercise tolerance. These signs and symptoms result when the heart is unable to generate a cardiac output sufficient to meet the body's demands. This guideline uses the term heart failure in preference to the commonly used "congestive heart failure" because many patients with heart failure do not manifest pulmonary or systemic congestion.

More than 2 million Americans suffer from the effects of heart failure, and about 400,000 new cases are diagnosed each year. Mortality is high, with 5-year mortality rates in the range of 50 percent. In addition, quality of life is often adversely affected by symptoms and reduced functional capacity.

The evaluation and care of patients with heart failure exacts a high economic price from society, with more than $10 billion in resources going to treatment of patients with heart failure each year. Table 1 provides estimates of total national expenditures of all patients with this condition based on the most recent evidence available. [1-5]

Table 1. Estimated Total Direct Economic Cost of Heart Failure in the United States

Type of Service | Number[a] (thousands) | Costs[b] (millions)
Hospital days | 5,800[c] | $7,500
Physician office visits | 3,000[d] | 690
Nursing home days (1985) | 17,000[e] | 1,900
Drugs | Not applicable | 230
Total direct costs | Not applicable | 10,320

[a] Estimated from total national numbers in each category multiplied by the proportion devoted to heart failure (based on International Classification of Diseases, 9th Revision [ICD-9] codes).[1]

[b] Estimated from total national expenses in each category[2] multiplied by the proportion of expenditures devoted to heart failure (based on ICD-9 codes).[1]

[c] National Hospital Discharge Survey, National Center for Health Statistics (NCHS) 1990.[3]

[d] National Ambulatory Medical Care Survey, NCHS, 1989.[4]

[e] National Nursing Home Survey, NCHS, 1985.[5]

According to information supplied by the Health Care Financing Administration, Medicare paid $2.4 billion in 1992 for 654,000 hospital admissions for patients with a principal diagnosis of heart failure. Actual hospital charges for Medicare patients were more than double this amount, totaling $5.6 billion (mean charge: $8,500). Thus, heart failure represents an important component of uncompensated hospital care. The in-hospital mortality rate for Medicare patients in 1992 was about 7 percent, which contrasts with 30-day mortality rates of about 15 percent for heart failure patients observed in three large studies of Medicare admissions from the 1980's. [6-8] Part of this discrepancy may be accounted for by the difference between in-hospital and 30-day mortality rates, but it is also possible that in-hospital mortality rates have improved over the past few years.

Because of the high prevalence of heart failure and the resulting high cost of caring for these patients, improvements in the quality of care-and in the practice of cost-effective care-could have a tremendous impact on costs and outcomes. Proper management of heart failure can reduce both morbidity and mortality from this condition, as summarized in Table 2. The greatest difference in mortality (about a 16-percent to 18-percent adjusted mortality reduction) has been observed with coronary artery bypass graft (CABG) surgery in patients with angina and impaired left-ventricular function and with use of the angiotensin-converting enzyme (ACE) inhibitor enalapril in patients with severe heart failure. [9, 10] The mortality reductions observed with other interventions have been smaller. However, when one considers the millions of people with heart failure or left-ventricular dysfunction, even the smaller reductions in mortality depicted in Table 2 may translate into hundreds of thousands of lives extended.

Table 2. Effects of Treatment on Mortality in Patients With Left-Ventricular Dysfunction or Clinical Heart Failure

Study Author, Year | Study Population | N | Duration of Followup (years) | Treatment | Mortality Rate (percent) | Absolute Mortality Difference[a] (percent) | Symptomatic Hypotension[b] (percent)
Surgical Management of Heart Failure or Left-Ventricular Dysfunction
Bounous et al., 1988[9] | First cardiac catheterization; EF ≥ 40% | | | CABG | 14[c] | 18(Operative mortality NR)
Bounous et al., 1988[9] | First cardiac catheterization; EF ≥ 40% | 710 | 3.0 | Medical | 32[c]
Medical Management of Left-Ventricular Dysfunction
Pfeffer et al. (SAVE), 1992[15] | 3-16 days after MI; EF ≥ 40%; no current heart failure | 2,231 | 3.5[d] | Captopril | 20.4 | 4.2 | 0.7
Pfeffer et al. (SAVE), 1992[15] | 3-16 days after MI; EF ≥ 40%; no current heart failure | 2,231 | 3.5[d] | Placebo | 24.6 | 4.2 | 0.7
SOLVD Investigators (SOLVD Prevention Trial), 1992[16] | EF ≥ 35%; no heart failure | 4,228 | 3.1[d] | Enalapril | 14.8 | NS | NR
SOLVD Investigators (SOLVD Prevention Trial), 1992[16] | EF ≥ 35%; no heart failure | 4,228 | 3.1[d] | Placebo | 15.8 | NS | NR
Medical Management of Heart Failure
Cohn et al. (VHeFT I), 1986[17] | Chronic heart failure,cardiac enlargement or EF < 45%, and MVO[sub 2] < 25 mL/kg/min | 642 | 3.0 | HYD/ISDN | 36.2 | 10.7 | NR
Cohn et al. (VHeFT I), 1986[17] | Chronic heart failure,cardiac enlargement or EF < 45%, and MVO[sub 2] < 25 mL/kg/min | 642 | 3.0 | Placebo | 46.9 | 10.7 | NR
CONSENSUS Trial Study Group, 1987[10] | New York Heart Association Class IV heart failure | 253 | 1.0 | Enalapril | 36.2 | 16.2 | 5.5
CONSENSUS Trial Study Group, 1987[10] | New York Heart Association Class IV heart failure | 253 | 1.0 | Placebo | 52.4 | 16.2 | 5.5
SOLVD Investigators (SOLVD Treatment Trial), 1991[18] | Chronic heart failure; EF ≥ 35% | 2,569 | 3.5[d] | Enalapril | 35.2 | 4.5 | 2
SOLVD Investigators (SOLVD Treatment Trial), 1991[18] | Chronic heart failure; EF ≥ 35% | 2,569 | 3.5[d] | Placebo | 39.7 | 4.5 | 2
Cohn et al. (VHeFT II), 1991[19] | Same as VHeFT I | 804 | 2.5[d] | Enalapril | 32.8 | 5.4 | 4.5
Cohn et al. (VHeFT II), 1991[19] | Same as VHeFT I | 804 | 2.5[d] | HYD/ISDN | 38.2 | 5.4 | 4.5

[a] All mortality differences are significant at p <0.05 except where indicated (NS).

[b] Symptomatic hypotension requiring termination of the study drug.

[c] Adjusted for baseline prognostic factors.

[d] Mean duration of followup.

Notes: NR = not reported, NS = not significant, HYD/ISDN = hydralazine and isosorbide dinitrate, CABG = coronary artery bypass graft, EF = ejection fraction, MI = myocardial infarction, MVO[sub 2] = maximum oxygen uptake, SAVE = Survival and Ventricular Enlargement, SOLVD = Studies of Left-Ventricular Dysfunction, VHeFT = Veterans Affairs Vasodilator Heart Failure Trial.

Conversely, poor quality care has been shown to have a negative impact on outcomes. Patients hospitalized with heart failure who received poor quality care, as defined by explicit, validated process criteria, experienced increased death rates in the 30 days following hospital discharge. [11] Despite improvements in the quality of care in recent years, this group of investigators found that 12 percent of patients hospitalized with heart failure received poor or very poor quality care. In addition, 7 percent of patients were thought to have been discharged too soon, and those discharged in unstable condition were found to have a 16-percent mortality rate at 90 days after discharge compared with 10 percent in those who were discharged in stable condition. [12]

Deficiencies have also been found in the quality of outpatient care. Retchin and Brown [13] found that less than half the patients they studied were advised to follow a salt-restricted diet. Many patients were found to have uncontrolled hypertension, but medications were initiated or modified in only 62 percent of fee-for-service (FFS) patients and 36 percent of patients in the health maintenance organization (HMO) groups. Twenty-seven percent of patients in the FFS group had a followup visit within 1 week of discharge from the hospital; 42 percent of HMO patients were seen within this period. Improved management of outpatients could reduce morbidity and mortality and decrease hospitalizations.

## Practice Variations

Fleg et al. [14] found differences in self-reported practice styles in the utilization of laboratory procedures to monitor outpatients with heart failure. In comparison with internists or family physicians, cardiologists were more likely to follow outpatients with heart failure by using echocardiography, radionuclide ventriculography, or exercise testing. The estimated yearly cost of following a patient with New York Heart Association (NYHA) Class II heart failure was $303 for the quartile of physicians with the lowest utilization of procedures compared with $1,167 for the highest quartile. If the average costs of such tests could be reduced by $250 per year, more than $500 million could be saved annually on a national basis.

## Common Errors in Management

As a way to organize the panel's thinking and to help ensure that the guideline has a positive impact on quality of care, the panel identified several aspects of the care of heart failure patients that are often not managed appropriately. This list was circulated to about 20 project consultants, who concurred on almost all points and added others. The complete list follows.

### Errors in Diagnosis

- Patients with symptoms suggestive of heart failure are often not thoroughly evaluated to rule out noncardiac causes before treatment for heart failure is instituted.
- Symptoms of heart failure may be attributed to chronic obstructive pulmonary disease (COPD) and treated inappropriately.
- Reversible causes of heart failure are not always identified, or if identified, they may be undertreated.
- Patients with peripheral edema may be inappropriately labeled as having heart failure when there is another cause for the edema.
- An initial measurement of left-ventricular function is not always obtained.
- Concurrent angina or other evidence of ischemia is not always properly evaluated.

### Errors in Evaluation and Testing

- Chest x-ray, electrocardiography, echocardiography, and radionuclide studies are commonly used for monitoring patients' progress, rather than symptom- or activity-based measures.
- Holter monitoring is overutilized, leading to unjustified treatment of asymptomatic ventricular arrhythmias.

### Errors in Management

- Coexistent hypertension is often not treated aggressively enough.
- Patient, family, and caregiver education is often inadequate.
- Patients with heart failure that is not due to systolic dysfunction may be treated inappropriately.
- Practitioners may not instruct patients to monitor their weight closely.
- Patient noncompliance and its causes are often not recognized and dealt with appropriately.
- The possibility of revascularization is often not considered in patients who have severe coronary artery disease with left-ventricular systolic dysfunction.
- Patients with severe heart failure are often referred too late for heart transplantation, after severe decompensation and the development of secondary multisystem organ failure.
- Exercise prescriptions are underutilized.
- ACE inhibitors are often not initiated or are prescribed at suboptimal doses because of clinicians' concerns about possible side effects.
- Physicians frequently prescribe inadequate doses of diuretics in patients who continue to have overt volume overload despite modest doses of diuretics.
- Practitioners may fail to appreciate the potentially deleterious effects of certain pharmacological agents in heart failure (e.g., calcium blockers, nonsteroidal anti-inflammatory agents, beta-agonist inhalers).

Each of these areas is addressed by this Clinical Practice Guideline.

## Scope of Guideline

This guideline focuses on the practical aspects of management of patients with heart failure due to reduced left-ventricular systolic performance (ejection fraction [EF] <35-40 percent). This area of heart failure management offers a great opportunity for improved clinical practice and, accordingly, for improved survival and health-related quality of life. The guideline panel elected not to address in detail the management of heart failure associated with diastolic dysfunction (i.e., heart failure associated with normal or elevated EF). This category of patients is quite heterogeneous, and there are very few data concerning the appropriate approach to these patients. Similarly, the guideline does not address medical management strategies specific to the in-hospital setting (e.g., pulmonary artery catheters or intra-aortic balloon pumps) or heart failure caused by surgically correctable valvular disease, aneurysm, or identifiable myocardial disease (e.g., amyloidosis, sarcoidosis). These topics may be suitable for future guidelines. Figure 1 depicts the overall organization and topics covered by this guideline.

Figure 1. Overview of Evaluation and Care of Patients With Heart Failure

## Methodology for Guideline Development

The guideline development process used during this project followed the evidence-based approach recommended by AHCPR. A 16-member expert panel was constituted to interpret and supplement the evidence available in published literature. Panelists were selected after a broad range of input was obtained from professional and health care consumer organizations and individuals. At least one professional or consumer organization nominated or endorsed each panel member. The panel consisted of five cardiologists, two cardiac surgeons, one internist-geriatrician, one general internist, one family physician, one pulmonologist, one clinical pharmacist, two nurses with expertise in cardiac care and research, and two consumer representatives. To help define and circumscribe the scope of the guideline and associated literature reviews, the panel co-chairs and project staff first developed a draft clinical algorithm. The algorithm is designed both to depict the scope of the guideline and to provide assistance with decisionmaking strategies for patients with heart failure and practitioners on a case-by-case basis. This draft algorithm was then considered by the full guideline panel at its first meeting, in February 1992.

To refine the guideline topic, the panel decided to focus the scope of the guideline on the evaluation and care of patients with left-ventricular systolic dysfunction and to exclude consideration of interventions specific to the inpatient setting (e.g., right-heart catheterization, mechanical assist devices).

To further focus the scope of the guideline and to ensure maximal impact of the guideline in actual clinical practice, the panel next developed a list of commonly seen errors in the outpatient management of heart failure, as already described. Project staff were charged with ensuring that the guideline addressed these areas of management. Because of the potentially very large number of topics available for review within the selected domain, and because time and budgetary restrictions prohibited an all-inclusive literature review, the panel rated topics to determine their priority for literature review.

Project staff then conducted comprehensive literature reviews in the selected areas, including (1) the use of echocardiography and radionuclide ventriculography for measuring left-ventricular function, (2) the use of revascularization, (3) the use of ACE inhibitors and other pharmacological agents, (4) patient education and compliance issues, and (5) followup monitoring. More than 1,000 articles were examined during this review. Of these, 237 were specifically used to develop the recommendations in this guideline and are cited in this document. A quality-assessment system (discussed below) was developed to rate methods used in these studies.

The literature reviews focused on the clinical benefits and harms (in terms of life expectancy and effects on quality of life) associated with each possible intervention and management strategy. Panelists weighed the expected benefits and harms of diagnostic and treatment strategies in order to derive their management recommendations. Costs of treatment were not explicitly taken into account when these recommendations were formulated, although the panel recognized the potential systemwide financial implications of those recommendations.

Results of the literature reviews were described in several reports prepared by project staff and distributed to panelists before the May 1992 panel meeting. Based on these reports, the panel formulated initial management recommendations for the diagnosis and treatment of heart failure patients.

On June 26, 1992, before its regular meeting, the panel convened a public open forum to give interested parties an opportunity to comment on any aspect of heart failure management of interest to them. Several organizations and individuals offered oral or written testimony that the panel considered during its subsequent deliberations. In subsequent meetings, the panel revised its management recommendations on the basis of continued evaluations of the literature, panel discussion, and input from project consultants.

During January and February 1993, a formal round of peer review was conducted in which the guideline document was circulated to about 40 professional organizations and individuals. Twenty-nine formal responses were obtained. The recommendations and suggestions contained in these responses were summarized for the panel, which considered them during its February 1993 meeting. The guideline was revised after this meeting.

Finally, a pilot review was conducted on the revised document in August 1993 to evaluate the usefulness, clarity, and feasibility of the Clinical Practice Guideline, Quick Reference Guide for Clinicians, and Patient and Family Guide. These documents were sent to 30 organizations and individuals representing primary care practitioners. Twenty responses were obtained. The strong consensus of reviewers who tried using the documents with patients was that the algorithm format provided a useful framework for applying the recommendations contained in the Clinical Practice Guideline and Quick Reference Guide for Clinicians to individual patients, particularly in complicated cases. Reviewers also believed that the structure of the documents was reasonably clear and user friendly. In addition to comments concerning the utility of the guideline in actual clinical settings, pilot reviewers also offered additional comments and recommendations. These were considered by the panel, and changes were made as appropriate.

## Literature Quality-Rating System

In developing an evidence-based guideline, the quality of the studies used by the panel to guide its recommendations is important. Project staff defined seven levels of evidence for the panel's use. The levels depended on the study design, the quality of the studies (discussed below), sample sizes, and the consistency of results across centers and studies. The seven levels were:

- I.
- Evidence from large, well-conducted randomized controlled trials (RCT's).
- II.
- Evidence from small, well-conducted RCT's.
- III.
- Evidence from well-conducted cohort studies.
- IV.
- Evidence from well-conducted case-control studies.
- V.
- Evidence from uncontrolled or poorly controlled studies.
- VI.
- Conflicting evidence, but tending to favor the recommendation.
- VII.
- Expert opinion.

A quality-rating system was developed based on the large body of work done in the area of meta-analysis. [20-24] The following principles were incorporated:

- The main focus of the rating system should be on the detection of methodologic flaws that might introduce enough bias to threaten the validity of a study's results. (These were considered major flaws.)
- Those elements that are unlikely to have a major influence on validity and may represent poor reporting or editing (minor flaws) should be recorded separately rather than being incorporated into a global score of quality.
- The criteria used for grading studies should be as explicit as possible.
- If the data from a study were analyzed incorrectly by the author and enough information is given to analyze the data correctly, the corrected results should be used.

Studies were assessed on eight aspects of method: patient selection, allocation of patients to treatments, description of the therapeutic regimen, study administration, withdrawals, patient blinding, outcome measurement, and statistical analysis. Specific criteria were defined for major and minor flaws in each aspect of method.

The classification scheme for the guideline document was later simplified into a three-level system for strength of evidence:

- A
- Good evidence: Evidence from well-conducted RCT's or cohort studies (Levels I-III).
- B
- Fair evidence: Evidence from other types of studies (Levels IV-VI).
- C
- Expert opinion (Level VII).

## Recommendations for Future Research

The heart failure guideline panel identified several areas related to diagnosis and treatment that were not addressed, or that were inadequately studied, in available literature. These topics constitute important areas for future research that could be addressed to the extent possible in updates of the guideline. Guideline updates are currently planned for this and other AHCPR-sponsored clinical practice guidelines.

Questions identified by the panel as in need of research were:

- 1. What are the current practice patterns for patients with heart failure?
  - How often are ACE inhibitors used?How often are heart failure patients hospitalized over the course of a year?
  - How many office visits do heart failure patients make during a year?
  - How often are various medications employed?
  - How often are echocardiograms and other noninvasive tests performed?
  - How often are heart failure patients revascularized?Are there geographic variations in management practices?

- 2. What are the costs associated with current patterns of treatment for heart failure patients?
  - Costs of office visits and hospitalizations.
  - Costs of testing.
  - Costs of medications.
  - Costs of revascularization.
  - Geographic variation in costs.

- 3. What are the sensitivity, specificity, and predictive value of noninvasive testing for ischemia in patients with heart failure? (For example, how often are positive noninvasive tests predictive of significant coronary lesions appropriate for revascularization?) Existing published data are based on patients with angina as their primary symptom.

- 4. What are the outcomes (e.g., mortality, functional status, quality of life) of revascularization (CABG versus percutaneous transluminal coronary angioplasty [PTCA]) in patients with heart failure, with or without significant angina? Again, most published outcomes data on revascularization apply to patients with angina as the predominant symptom. In addition, surgical techniques have changed since the time of most available studies.

- 5. Can patients play a more active role in their own management? Several panelists are interested in developing and testing a patient-centered self-management protocol that would incorporate patient preferences. One aspect of this protocol would probably address drug dose titration techniques according to patient-measured endpoints (e.g., daily weights). Protocol evaluation would address the outcomes (e.g, hospitalization, patient-reported health and functional status), costs, and patient satisfaction associated with the experimental intervention versus control.

- 6. What is the best way to initiate and titrate drug therapy? A study of the cost, patient acceptance, and outcomes associated with sequential versus combined administration of common pharmacological agents (e.g., diuretics, ACE inhibitors, digoxin) would be desirable.

- 7. What is the value of anticoagulation in heart failure patients?

- 8. What are patient preferences and expectations for several key areas of management?
  - Medical versus surgical management approaches.
  - Rehabilitation and exercise programs.
  - Compliance with salt- and alcohol-restricted diets.
  - Quality-of-life aspects of living with heart failure and its treatments.

- 9. How can the built-in biases of tertiary center data bases be overcome in analyzing practice patterns, outcomes, and associated costs? Panelists have suggested that a national heart failure patient registry should be established at several different practice environments. A standard set of variables would be coded, including descriptions of the presence/absence/degree of concomitant angina, management strategies pursued, costs, and outcomes.

- 10. What criteria should be used to follow patients and determine their response to treatment? Current evidence suggests that available clinical tests (e.g., echocardiogram) do not provide information pertaining to changes in patient prognosis or quality of life. Development and testing of functional health status and quality-of-life measures for use in the heart failure population could prove extremely valuable by providing endpoints for monitoring patient response to treatment.

- 11. Given the poor prognosis associated with heart failure and the lack of donor hearts, what is the role of new and innovative forms of treatment (e.g., mechanical assist devices)?

- 12. What is the impact of heart failure on patients' families? How do family members or other caregivers respond to the burden of caring for these patients?

- 13. What interventions improve compliance with low-sodium diets, exercise or activity recommendations, and medication regimens?

- 14. What nonpharmacological interventions (e.g., family and patient support groups, strategies to improve psychosocial status) improve patients' and families' ability to cope with heart failure?

- 15. What will be the impact of this and other guidelines on clinical practice and outcomes?